# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows (in addition to the Key Informants noted above that also served as Peer Reviewers):

- Daniel P. Alford, M.D., M.P.H.
  Associate Professor of Medicine
  Director
  Clinical Addiction Research and Education (CARE) Unit
  Boston University School of Medicine Boston Medical Center
  Boston, MA
- Mady Chalk, Ph.D., M.S.W.
  Director of Performance-based Policy
  Treatment Research Institutes
  Philadelphia, PA
- Kimberly Johnson, M.B.A., Ph.D.
  Director
  Center for Substance Abuse Treatment
  Rockville, MD
- Anna Lemke, M.D.
  Assistant Professor of Psychiatry and Behavioral Sciences
  Stanford University
  Stanford, CA
- Kevin Sevarino, M.D., Ph.D.
  Assistant Clinical Professor, Yale University
  Medical Director, Veteran’s Administration
  New Haven, CT