# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Carlos Blanco, M.D., Ph.D.
  Director Division of Epidemiology, Services and Prevention Research
  National Institute on Drug Abuse
  Bethesda, MD
- Kathleen Carroll, Ph.D.
  Professor of Psychiatry
  Yale University School of Medicine
  New Haven, CT
- ^*^David A. Fiellin, M.D.
  Professor of Medicine, Investigative Medicine and Public Health
  Yale University School of Medicine
  New Haven, CT
- Henrick Harwood, B.A.
  Director, Research and Program Applications
  of the National Association of State Alcohol and Drug Abuse Directors
  Washington DC
- Janice Kauffman, R.N., M.P.H.
  Vice President
  American Association for the Treatment of Opioid Dependence
  New York, NY
  (Also participated as a public reviewer of the draft report.)
- ^*^Colleen LaBelle MSN, RN-BC, CARN
  Program Director STATE OBAT
  Nurse Manager OBAT Boston Medical Center
- ^*^Michelle Lofwall, M.D.
  Associate Professor of Behavioral Science Psychiatry
  University of Kentucky College of Medicine
  Center on Drug and Alcohol Research
  Lexington, KY
- ^*^Sherrye C. McManus, Ph.D.
  Public Health Advisor
  Medication Assisted Treatment-Prescription Drug and Opioid Addiction Grant Program
  Substance Abuse & Medical Health Services Administration
  Rockville, MD
- Susan Robilotto, D.O.
  Clinical Consultant/Medical Officer
  US Department of Health and Human Services
  Health Resources and Services Administration
  HIV/AIDS Bureau
  Rockville, MD
- ^*^Jim Shames, M.D.
  Medical Director/Health Officer
  Jackson County
  Medford, OR
- Zac Talbott, CMA
  Peer Recovery Network Administrator
  Medication-Assisted Recovery Services
  Marysville, TN

* These individuals also participated as peer reviewers.