# Background

## Introduction

Opioid use disorder (OUD) has been identified by the Department of Health & Human Services as a national crisis.^1^ OUD involves misuse of prescription opioids or use of illicit heroin, and is defined by the Diagnostic and Statistical Manual of Mental Disorders (DSM-5)^2^ as “a problematic pattern of opioid use leading to clinically significant impairment or distress.” In 2014, approximately 1.9 million Americans 12 years or older were estimated to have OUD due to prescription drugs and nearly 600,000 due to heroin use.^3^ OUD is associated with decreased quality of life and increased morbidity and mortality. In 2013, an estimated 16,000 individuals died as a result of prescription opioid overdose (a 2.5-fold increase from 2001) and approximately 8,000 from heroin (a 4-fold increase from 2001).^4^ These trends have occurred in conjunction with markedly increased rates of opioid prescribing for chronic pain;^5–9^ in fact, the majority of heroin users now report that their first opioid of misuse was a prescription opioid, not heroin.^10^ Challenges in the treatment of OUD include the relapsing nature of this condition, the frequent presence of psychiatric and medical comorbidities, and the disproportionate impact on those in socioeconomically disadvantaged settings with limited access to care.^11,12^ Lack of control over purity leading to high variability in dose is an additional concern with heroin as compared with prescription opioids.

As noted in 1997 by a National Institutes of Health consensus panel, OUD “is a medical disorder that can be effectively treated with significant benefits for the patient and society.”^13^ According to the Substance Abuse and Mental Health Services Administration (SAMHSA), medication-assisted treatment (MAT) is defined as the use of the U.S. Food and Drug Administration (FDA)-approved opioid agonist medications (e.g., methadone, buprenorphine products, including buprenorphine/naloxone combination formulations and buprenorphine mono-product formulations [including a recently approved implantable formulation]) for the maintenance treatment of OUD, and opioid antagonist medications (e.g., naltrexone products, including extended-release and oral formulations), in combination with behavioral therapies, to prevent relapse to opioid use. MAT includes screening, assessment (which includes determination of severity of OUD, including presence of physical dependence and appropriateness for MAT), and case management. It has been suggested that the term MAT is misleading because it implies that medications play an adjunctive role in treatment for OUD, and that it would be more accurate to simply refer to multimodal therapy for OUD that includes use of medications as “treatment.”^14,15^ In this report, we use the term MAT because it is widely used, well-understood (as defined by SAMHSA), and to help distinguish medication-based from nonmedication based (e.g., detoxification/abstinence) approaches. The term MAT is not meant to imply that medications play an ancillary role in treatment; rather, medications are central to the concept of effective multimodal treatment for OUD. Medication is to be provided in combination with comprehensive substance use disorder treatment, including but not limited to: counseling, behavioral therapies, other clinically appropriate services in order for individuals to achieve and maintain abstinence from all opioids and heroin, and, when needed, pharmacotherapy for co-occurring alcohol use disorder. MAT is to be provided in a clinically-driven, person-centered, and individualized setting.”^16^ MAT has been shown to be more effective than treatments that do not use medication in reducing the frequency and quantity of opioid use^17,18^ and may reduce the risk of overdose, improving social functioning and decreasing criminal activity and infectious disease rates.^19^ The purpose of the medication component is to block the euphoric and sedating effects of opioids, reduce the craving for opioids, and/or mitigate the symptoms of opioid withdrawal. Psychosocial interventions address the psychosocial contributors to OUD and may help improve retention in care. Examples of psychosocial interventions include cognitive-behavioral therapy, motivational enhancement therapy, and other evidence-based psycho-social interventions in individual, group, or family counseling settings; peer-delivered recovery support services; and assessment, coordination, and management of other medical and psychiatric care needs such as provision of general primary care or treatment for other substances use disorders, HIV or hepatitis C virus (HCV) coinfection, or pregnancy.^20^ In addition, comorbid psychiatric disorders are frequently present in patients with OUD and may require treatment with psychiatric medications.

### Current Practices

The White House and the Department of Health & Human Services recently identified improved access to MAT as a key priority for reducing harms associated with OUD.^1,21^ Following the passage of the Harrison Narcotic Act in 1914 and prior to the Drug Abuse Treatment Act (DATA) of 2000, MAT using opioid agonists could only be provided through federally-approved opioid treatment programs and the partial opioid agonist buprenorphine was not yet approved for the treatment of OUD.^22^ DATA 2000 enabled physicians to obtain a waiver and prescribe for treatment of OUD schedule III–V medications approved by the FDA for this purpose; currently the only such medication is buprenorphine (also available coformulated with the opioid antagonist naloxone). An implantable formulation of buprenorphine was recently approved by the FDA. Under federal law, physicians prescribing opioid agonists for OUD must attest to the fact that they have access to ancillary counseling services. Although DATA 2000 has increased access to buprenorphine in primary care settings, research indicates that access to and use of buprenorphine remains limited.^4,23^ In many rural areas, for example, no buprenorphine prescribers are available.^24^ Oral naltrexone, an opioid antagonist, has long been available for treatment of OUD and extended-release naltrexone is recently available as a monthly intramuscular injection. Naltrexone is not classified as a controlled substance and can be prescribed in primary care settings by any physician, physician assistant, or nurse practitioner, but its use has been limited. Extended-release naltrexone was approved by the FDA for treatment of OUD in 2010; although oral naltrexone has long been available it is rarely used for this indication. Although extended-release naltrexone does not require a waiver to prescribe for OUD, its use currently appears low in comparison to buprenorphine, though reliable estimates on utilization are not available. Methadone for treatment of OUD is a schedule II opioid that is dispensed in licensed opioid-treatment programs (OTPs). Even in specialty substance use disorder settings, medications approved for MAT appear to be underused, with one study showing that MAT was used in only about one-third of patients.^25^ Therefore, understanding the most effective and promising models of care and implementation strategies are critical for optimizing the impact of initiatives to expand access to MAT.^1^

### Objective of Technical Brief

The purpose of this Technical Brief is to conduct a scoping review describing the available literature on MAT models of care and methods for effective MAT strategies, and to identify and summarize key issues and gaps in the evidence base. A Technical Brief does not synthesize data on outcomes or grade evidence. Rather, it seeks to summarize what evidence is available, provide a conceptual or organizational framework to understand key components of the intervention of interest, highlight promising new and innovative strategies, describe barriers to implementation, and provide guidance regarding future research directions and priorities. The focus of the Technical Brief is on implementation of MAT in primary care settings, including rural or other underserved settings. Specifically, Guiding Question 1 provides an overview of MAT models of care, Guiding Question 2 describes the context in which MAT is implemented, Guiding Question 3 summarizes the current state of the evidence of MAT, and Guiding Question 4 addresses important issues and future directions for MAT. This technical brief is intended to help determine the scope of future research, such as a subsequent systematic evidence review on MAT.

## Guiding Questions

1. Description/Overview of MAT for the Treatment of Opioid Use Disorder:
  a. What are the different types or models of care of MAT that have been proposed or used in clinical practice?
  b. What are the potential advantages and disadvantages of these respective models of care?
2. Context in Which MAT is Used:
  a. In what settings is MAT currently implemented?
  b. Are there special considerations for implementing MAT in primary care, including rural or other underserved settings?
  c. What are potential barriers to implementation, including resources needed, and how do barriers vary according to the setting?
  d. What kinds of training, certification, and staffing are required for various MAT models of care?
3. Current Evidence on MAT:
  a. What have published and unpublished studies reported on the use of and effectiveness MAT in primary care settings, including rural or other underserved settings? The technical brief will summarize the following information:
    i. Patient population, including practice setting and country/location
    ii. Details on MAT model of care, including the types of interventions used (specifics of pharmacological and nonpharmacological treatments), provider type/staffing needs, implementation strategy/mode of delivery, frequency, and other factors
    iii. Study design/size
    iv. Comparator used in comparative studies
    v. Concurrent/prior treatments
    vi. Length of followup
    vii. Outcomes measured
    viii. Adverse events/harms/safety issues reported
4. Important Issues and Future Directions for MAT:
  a. What are promising new and innovative strategies in MAT models of care?
  b. Given the current state of the evidence, what are the implications for the current level of diffusion and/or further diffusion of MAT?
  c. What are the ethical, equity, and/or cost considerations that impact diffusion, decisionmaking, and/or conceptual thinking around MAT?
  d. What are important areas of uncertainty for MAT?
  e. What are possible key areas of future research on MAT, and what areas related to MAT warrant a systematic review?