# Appendix E Excluded Studies List

Counseling Conditons for Thrice Weekly BUP in a PCC.
Opiate Dependence: Combined Naltrexone/behavior Therapy.
(2003). Buprenorphine combined with counseling found effective in reducing relapse. Alcoholism & Drug Abuse Weekly.
Aalto M, Visapaa JP, Halme JT, et al. (2011). Effectiveness of buprenorphine maintenance treatment as compared to a syringe exchange program among buprenorphine misusing opioid-dependent patients. Nord J Psychiatry.
Ahamad K, Milloy MJ, Nguyen P, et al. (2015). Factors associated with willingness to take extended release naltrexone among injection drug users. Addict Sci Clin Pract.
Allen MA, Jewers H, McDonald JS. (2014). A Framework for the Treatment of Pain and Addiction in the Emergency Department. JEN.
Amass L, Pukeleviciene V, Subata E, et al. (2012). A prospective, randomized, multicenter acceptability and safety study of direct buprenorphine/naloxone induction in heroin-dependent individuals. Addiction.
Amato L, Davoli M, Minozzi S, et al. (2013). Methadone at tapered doses for the management of opioid withdrawal. Cochrane Database Syst Rev.
Amato L, Minozzi S, Davoli M, et al. (2004). Psychosocial combined with agonist maintenance treatments versus agonist maintenance treatments alone for treatment of opioid dependence. Cochrane Database Syst Rev.
(2003). Treatment of opiate dependence in hands of primary care providers. Public Health Rep.
(2005). Public policy statement on Office-Based Opioid Agonist Treatment (OBOT). J Addict Dis.
Apelt SM, Scherbaum N, Golz J, et al. (2013). Safety, effectiveness and tolerance of buprenorphine-naloxone in the treatment of opioid dependence: results from a nationwide non-interventional study in routine care. Pharmacopsychiatry.
Aszalos R, McDuff DR, Weintraub E, et al. (1999). Engaging hospitalized heroin-dependent patients into substance abuse treatment. J Subst Abuse Treat.
Barnett PG, Masson CL, Sorensen JL, et al. (2006). Linking opioid-dependent hospital patients to drug treatment: Health care use and costs 6 months after randomization. Addiction.
Barry DT, Moore BA, Pantalon MV, et al. (2007). Patient satisfaction with primary care office-based buprenorphine/naloxone treatment. J Gen Intern Med.
Bassuk EL, Hanson J, Greene RN, et al. (2016). Peer-Delivered Recovery Support Services for Addictions in the United States: A Systematic Review. J Subst Abuse Treat.
Berger R, Pulido C, Lacro J, et al. (2014). Group medication management for buprenorphine/naloxone in opioid-dependent veterans. J Addict Med.
Bonhomme J, Shim RS, Gooden R, et al. (2012). Opioid addiction and abuse in primary care practice: a comparison of methadone and buprenorphine as treatment options. J Natl Med Assoc.
Brands B, Blake J, Marsh D. (2002). Changing patient characteristics with increased methadone maintenance availability. Drug Alcohol Depend.
Bryson WC, McConnell J, Korthuis PT, et al. (2011). Extended-release naltrexone for alcohol dependence: persistence and healthcare costs and utilization. Am J Manag Care.
Burns L, Mattick RP, Lim K, et al. (2007). Methadone in pregnancy: treatment retention and neonatal outcomes. Addiction.
Caldiero RM, Parran TV, Adelman CL, et al. (2006). Inpatient initiation of buprenorphine maintenance vs. detoxification: can retention of opioid-dependent patients in outpatient counseling be improved?. Am J Addict.
Carroll KM, Ball SA, Martino S, et al. (2008). Computer-assisted delivery of cognitive-behavioral therapy for addiction: a randomized trial of CBT4CBT. Am J Psychiatry.
Center for Substance Abuse Treatment. (2005). Medication-Assisted Treatment for Opioid Addiction in Opioid Treatment Programs.
Chawarski MC, Mazlan M, Schottenfeld RS. (2008). Behavioral drug and HIV risk reduction counseling (BDRC) with abstinence-contingent take-home buprenorphine: a pilot randomized clinical trial. Drug Alcohol Depend.
Chua SM, Lee TS. (2006). Abuse of prescription buprenorphine, regulatory controls and the role of the primary physician. Ann Acad Med Singapore.
Clay E, Khemiri A, Zah V, et al. (2014). Persistence and healthcare utilization associated with the use of buprenorphine/naloxone film and tablet formulation therapy in adults with opioid dependence. J Med Econ.
Colameco S, Armando J, Trotz C. (2005). Opiate dependence treatment with buprenorphine: one year’s experience in a family practice residency setting. J Addict Dis.
Colson J, Helm S, Silverman SM. (2012). Office-based opioid dependence treatment. Pain physician.
Connery HS. (2015). Medication-assisted treatment of opioid use disorder: review of the evidence and future directions. Harv Rev Psychiatry.
Copenhaver MM, Bruce RD, Altice FL. (2007). Behavioral counseling content for optimizing the use of buprenorphine for treatment of opioid dependence in community-based settings: a review of the empirical evidence. Am J Drug Alcohol Abuse.
Cozzolino E, Guglielmino L, Vigezzi P, et al. (2006). Buprenorphine treatment: a three-year prospective study in opioid-addicted patients of a public out-patient addiction center in Milan. Am J Addict.
Cunningham C, Giovanniello A, Sacajiu G, et al. (2008). Buprenorphine treatment in an urban community health center: what to expect. Fam Med.
Cunningham CO, Giovanniello A, Li X, et al. (2011). A comparison of buprenorphine induction strategies: patient-centered home-based inductions versus standard-of-care office-based inductions. J Subst Abuse Treat.
Cunningham CO, Giovanniello A, Sacajiu G, et al. (2009). Inquiries about and initiation of buprenorphine treatment in an inner-city clinic. Substance abuse.
Cunningham CO, Roose RJ, Starrels JL, et al. (2013). Prior buprenorphine experience is associated with office-based buprenorphine treatment outcomes. J Addict Med.
Daniels AM, Salisbury-Afshar E, Hoffberg A, et al. (2014). A novel community-based buprenorphine program: client description and initial outcomes. J Addict Med.
Davies D. (2005). Buprenorphine versus methadone--safety first?. Br J Gen Pract.
De Ducla M, Gagnon A, Mucchielli A, et al. (2000). Comparison of high dose buprenorphine treatments of opiate dependent outpatients in four healthcare networks. Ann Med Interne (Paris).
DeFulio A, Everly JJ, Leoutsakos JM, et al. (2012). Employment-based reinforcement of adherence to an FDA approved extended release formulation of naltrexone in opioid-dependent adults: a randomized controlled trial. Drug Alcohol Depend.
Donaher PA, Welsh C. (2006). Managing opioid addiction with buprenorphine. Am Fam Physician.
Doolittle B, Becker W. (2011). A case series of buprenorphine/naloxone treatment in a primary care practice. Substance abuse.
Drainoni ML, Farrell C, Sorensen-Alawad A, et al. (2014). Patient perspectives of an integrated program of medical care and substance use treatment. AIDS Patient Care STDS.
Ducharme S, Fraser R, Gill K. (2012). Update on the clinical use of buprenorphine: in opioid-related disorders. Can Fam Physician.
Everly JJ, DeFulio A, Koffarnus MN, et al. (2011). Employment-based reinforcement of adherence to depot naltrexone in unemployed opioid-dependent adults: a randomized controlled trial. Addiction.
Fals-Stewart W, O’Farrell TJ. (2003). Behavioral family counseling and naltrexone for male opioid-dependent patients. J Consult Clin Psychol.
Fareed A, Eilender P, Ketchen B, et al. (2014). Factors affecting noncompliance with buprenorphine maintenance treatment. J Addict Med.
Fareed A, Vayalapalli S, Casarella J, et al. (2012). Treatment outcome for flexible dosing buprenorphine maintenance treatment. Am J Drug Alcohol Abuse.
Ferner RE, Daniels AM. (2003). Office-based treatment of opioid-dependent patients. N Engl J Med.
Ferri M, Davoli M, Perucci CA. (2011). Heroin maintenance for chronic heroin-dependent individuals. Cochrane Database Syst Rev.
Ferri M, Finlayson AJ, Wang L, et al. (2014). Predictive factors for relapse in patients on buprenorphine maintenance. Am J Addict.
Fiellin DA. (2006). Buprenorphine: effective treatment of opioid addiction starts in the office. Am Fam Physician.
Fiellin DA, O’Connor PG. Office-Based Treatment of Opioid-Dependent Patients.
Fiellin DA, O’Connor PG. (2002). Clinical practice Office-based treatment of opioid-dependent patients. N Engl J Med.
Fiellin DA, O’Connor PG, Chawarski M, et al. (2004). Processes of care during a randomized trial of office-based treatment of opioid dependence in primary care. Am J Addict.
Fiellin DA, Schottenfeld RS, Cutter CJ, et al. (2014). Primary care-based buprenorphine taper vs maintenance therapy for prescription opioid dependence: a randomized clinical trial. JAMA Intern Med.
Fingerhood MI, King VL, Brooner RK, et al. (2014). A comparison of characteristics and outcomes of opioid-dependent patients initiating office-based buprenorphine or methadone maintenance treatment. Substance abuse.
Fischer G, Etzersdorfer P, Eder H, et al. (1998). Buprenorphine maintenance in pregnant opiate addicts. Eur Addict Res.
Fischer G, Johnson RE, Eder H, et al. (2000). Treatment of opioid-dependent pregnant women with buprenorphine. Addiction.
Fischer G, Ortner R, Rohrmeister K, et al. (2006). Methadone versus buprenorphine in pregnant addicts: a double-blind, double-dummy comparison study. Addiction.
Fishman MJ, Winstanley EL, Curran E, et al. (2010). Treatment of opioid dependence in adolescents and young adults with extended release naltrexone: preliminary case-series and feasibility. Addiction.
French MT. (2001). Cost-effectiveness of buprenorphine maintenance versus methadone maintenance. Addiction.
George S. (2010). Review: methadone increases retention and reduces heroin use compared with non-pharmacological maintenance. Evidence Based Mental Health.
Giacomuzzi SM, Riemer Y, Ertl M, et al. (2003). Buprenorphine versus methadone maintenance treatment in an ambulant setting: a health-related quality of life assessment. Addiction.
Gordon AJ, Trafton JA, Saxon AJ, et al. (2007). Implementation of buprenorphine in the Veterans Health Administration: results of the first 3 years. Drug Alcohol Depend.
Gossop M, Marsden J, Stewart D, et al. (2003). The National Treatment Outcome Research Study (NTORS): 4–5 year follow-up results. Addiction.
Gossop M, Marsden J, Stewart D, et al. (1999). Methadone treatment practices and outcome for opiate addicts treated in drug clinics and in general practice: results from the National Treatment Outcome Research Study. Br J Gen Pract.
Gossop M, Stewart D, Browne N, et al. (2003). Methadone treatment for opiate dependent patients in general practice and specialist clinic settings: Outcomes at 2-year follow-up. J Subst Abuse Treat.
Gourevitch MN, Chatterji P, Deb N, et al. (2007). On-site medical care in methadone maintenance: associations with health care use and expenditures. J Subst Abuse Treat.
Haddad MS, Zelenev A, Altice FL. (2013). Integrating buprenorphine maintenance therapy into federally qualified health centers: real-world substance abuse treatment outcomes. Drug Alcohol Depend.
Haddad MS, Zelenev A, Altice FL. (2015). Buprenorphine maintenance treatment retention improves nationally recommended preventive primary care screenings when integrated into urban federally qualified health centers. J Urban Health.
Harris KA, Arnsten JH, Joseph H, et al. (2006). A 5-year evaluation of a methadone medical maintenance program. J Subst Abuse Treat.
Herman M, Gourevitch MN. (1997). Integrating primary care and methadone maintenance treatment: implementation issues. J Addict Dis.
Hersh D, Little SL, Gleghorn A. (2011). Integrating buprenorphine treatment into a public healthcare system: the San Francisco Department of Public Health’s office-based Buprenorphine Pilot Program. J Psychoactive Drugs.
Hulse GK. (2010). Subcutaneous naltrexone implants reduce opioid use in opiate dependent patients. Evid Based Ment Health.
Hulse GK, Morris N, Arnold-Reed D, et al. (2009). Improving clinical outcomes in treating heroin dependence: randomized, controlled trial of oral or implant naltrexone. Arch Gen Psychiatry.
Hulse GK, O’Neil G, Arnold-Reed DE. (2004). Methadone maintenance vs. implantable naltrexone treatment in the pregnant heroin user. Int J Gynaecol Obstet.
Hulse GK, Tait RJ, Comer SD, et al. (2005). Reducing hospital presentations for opioid overdose in patients treated with sustained release naltrexone implants. Drug Alcohol Depend.
Imani S, Vahid MKA, Gharraee B, et al. (2015). Comparing mindfulness-based group therapy with treatment as usual for opioid dependents: A pilot randomized clinical trial study protocol. Iran J Psychiatry Behav Sci.
Jamison RN, Kauffman J, Katz NP. (2000). Characteristics of methadone maintenance patients with chronic pain. J Pain Symptom Manage.
King VL, Burke C, Stoller KB, et al. (2008). Implementing methadone medical maintenance in community-based clinics: disseminating evidence-based treatment. J Subst Abuse Treat.
King VL, Stoller KB, Hayes M, et al. (2002). A multicenter randomized evaluation of methadone medical maintenance. Drug Alcohol Depend.
Kouimtsidis C, Reynolds M, Coulton S, et al. (2012). How does cognitive behaviour therapy work with opioid-dependent clients? Results of the UKCBTMM Study. Drugs: Educ Prev Polic.
Kresina TF, Eldred L, Bruce RD, et al. (2005). Integration of pharmacotherapy for opioid addiction into HIV primary care for HIV/hepatitis C virus-co-infected patients. Aids.
Krupitsky E, Nunes EV, Ling W, et al. (2011). Injectable extended-release naltrexone for opioid dependence: a double-blind, placebo-controlled, multicentre randomised trial. Lancet.
Krupitsky E, Zvartau E, Blokhina E, et al. (2012). Randomized trial of long-acting sustained-release naltrexone implant vs oral naltrexone or placebo for preventing relapse to opioid dependence. Arch Gen Psychiatry.
Kuhn S, Schu M, Vogt I, et al. (2007). Psychosocial care in the German model project on heroin-maintenance therapy for opiate dependence. Sucht.
Kunoe N, Lobmaier P, Vederhus JK, et al. (2010). Challenges to antagonist blockade during sustained-release naltrexone treatment. Addiction.
Kunoe N, Lobmaier P, Vederhus JK, et al. (2009). Naltrexone implants after in-patient treatment for opioid dependence: randomised controlled trial. Br J Psychiatry.
Kunoe N, Lobmaier P, Vederhus JK, et al. (2010). Retention in naltrexone implant treatment for opioid dependence. Drug Alcohol Depend.
Kurdyak P, Gomes T, Yao Z, et al. (2012). Use of other opioids during methadone therapy: a population-based study. Addiction.
Lacroix I, Berrebi A, Garipuy D, et al. (2011). Buprenorphine versus methadone in pregnant opioid-dependent women: a prospective multicenter study. Eur J Clin Pharmacol.
Langendam MW, van Brussel GH, Coutinho RA, et al. (2001). The impact of harm-reduction-based methadone treatment on mortality among heroin users. A J Public Health.
Lapeyre-Mestre M, Llau ME, Gony M, et al. (2003). Opiate maintenance with buprenorphine in ambulatory care: a 24-week follow-up study of new users. Drug Alcohol Depend.
Larance B, Degenhardt L, O’Brien S, et al. (2011). Prescribers’ perceptions of the diversion and injection of medication by opioid substitution treatment patients. Drug Alcohol Rev.
Lavie E, Fatseas M, Denis C, et al. (2009). Benzodiazepine use among opiate-dependent subjects in buprenorphine maintenance treatment: correlates of use, abuse and dependence. Drug Alcohol Depend.
Lavignasse P, Lowenstein W, Batel P, et al. (2002). Economic and social effects of high-dose buprenorphine substitution therapy. Six-month results. Ann Med Interne (Paris).
Lawental E. (2000). Ultra rapid opiate detoxification as compared to 30-day inpatient detoxification program--a retrospective follow-up study. J Subst Abuse.
Lawrinson P, Roche A, Terao H, et al. (2008). Dispensing opioid substitution treatment: practices, attitudes and intentions of community-based pharmacists. Drug Alcohol Rev.
Lee CT, Chen VC, Tan HK, et al. (2013). Suicide and other-cause mortality among heroin users in Taiwan: a prospective study. Addict Behav.
Lee J, Kresina TF, Campopiano M, et al. (2015). Use of pharmacotherapies in the treatment of alcohol use disorders and opioid dependence in primary care. Biomed Res Int.
Lee JD, Friedmann PD, Boney TY, et al. (2015). Extended-release naltrexone to prevent relapse among opioid dependent, criminal justice system involved adults: rationale and design of a randomized controlled effectiveness trial. Contemp Clin Trials.
Lee JD, Grossman E, DiRocco D, et al. (2009). Home buprenorphine/naloxone induction in primary care. J Gen Intern Med.
Lee JD, Grossman E, Truncali A, et al. (2012). Buprenorphine-naloxone maintenance following release from jail. Substance abuse.
Lee JD, Vocci F, Fiellin DA. (2014). Unobserved “home” induction onto buprenorphine. J Addict Med.
Lejeune C, Simmat-Durand L, Gourarier L, et al. (2006). Prospective multicenter observational study of 260 infants born to 259 opiate-dependent mothers on methadone or high-dose buprenophine substitution. Drug Alcohol Depend.
Ling W, Amass L, Shoptaw S, et al. (2005). A multi-center randomized trial of buprenorphine-naloxone versus clonidine for opioid detoxification: findings from the National Institute on Drug Abuse Clinical Trials Network. Addiction.
Ling W, Casadonte P, Bigelow G, et al. (2010). Buprenorphine implants for treatment of opioid dependence: a randomized controlled trial. JAMA.
Ling W, Hillhouse M, Ang A, et al. (2013). Comparison of behavioral treatment conditions in buprenorphine maintenance. Addiction.
Lintzeris N, Lenne M, Ritter A. (1999). Methadone injecting in Australia: a tale of two cities. Addiction.
Lintzeris N, Leung SY, Dunlop AJ, et al. (2013). A randomised controlled trial of sublingual buprenorphine-naloxone film versus tablets in the management of opioid dependence. Drug Alcohol Depend.
Liu TT, Shi J, Epstein DH, et al. (2009). A meta-analysis of acupuncture combined with opioid receptor agonists for treatment of opiate-withdrawal symptoms. Cell Mol Neurobiol.
Lobmaier PP, Kunoe N, Gossop M, et al. (2010). Naltrexone implants compared to methadone: outcomes six months after prison release. Eur Addict Res.
Longman C, Lintzeris N, Temple-Smith M, et al. (2011). Methadone and buprenorphine prescribing patterns of Victorian general practitioners: their first 5 years after authorisation. Drug Alcohol Rev.
Longshore D, Annon J, Anglin MD, et al. (2005). Levo-alpha-acetylmethadol (LAAM) versus methadone: treatment retention and opiate use. Addiction.
Luthar SS, Suchman NE. (2000). Relational Psychotherapy Mothers’ Group: a developmentally informed intervention for at-risk mothers. Dev Psychopathol.
Madden ME, Shapiro SL. (2011). The methadone epidemic: methadone-related deaths on the rise in Vermont. Am J Forensic Med Pathol.
Maddux JF, Desmond DP, Vogtsberger KN. (1995). Patient-regulated methadone dose and optional counseling in methadone maintenance. American J Addiction.
Magura S, Lee SJ, Salsitz EA, et al. (2007). Outcomes of buprenorphine maintenance in office-based practice. J Addict Dis.
Mannelli P, Patkar AA, Peindl K, et al. (2009). Very low dose naltrexone addition in opioid detoxification: a randomized, controlled trial. Addict Biol.
Mannelli P, Patkar AA, Peindl K, et al. (2007). Effectiveness of low-dose naltrexone in the post-detoxification treatment of opioid dependence. J Clin Psychopharmacol.
Mannelli P, Peindl KS, Lee T, et al. (2012). Buprenorphine-mediated transition from opioid agonist to antagonist treatment: state of the art and new perspectives. Curr Drug Abuse Rev.
March JC, Oviedo-Joekes E, Perea-Milla E, et al. (2006). Controlled trial of prescribed heroin in the treatment of opioid addiction. J Subst Abuse Treat.
Maremmani I, Pani PP, Pacini M, et al. (2007). Substance use and quality of life over 12 months among buprenorphine maintenance-treated and methadone maintenance-treated heroin-addicted patients. J Subst Abuse Treat.
Marsch LA, Guarino H, Acosta M, et al. (2014). Web-based behavioral treatment for substance use disorders as a partial replacement of standard methadone maintenance treatment. J Subst Abuse Treat.
Marsden J, Eastwood B, Bradbury C, et al. (2009). Effectiveness of community treatments for heroin and crack cocaine addiction in England: a prospective, in-treatment cohort study. Lancet.
Maxwell JC, Pullum TW, Tannert K. (2005). Deaths of clients in methadone treatment in Texas: 1994–2002. Drug Alcohol Depend.
Maxwell S, Shinderman M. (1999). Optimizing response to methadone maintenance treatment: use of higher-dose methadone. J Psychoactive Drugs.
Maxwell S, Shinderman MS. (2002). Optimizing long-term response to methadone maintenance treatment: a 152-week follow-up using higher-dose methadone. J Addict Dis.
McHugh RK, Murray HW, Hearon BA, et al. (2013). Predictors of dropout from psychosocial treatment in opioid-dependent outpatients. Am J Addict.
McKeganey N, Russell C, Cockayne L. (2013). Medically assisted recovery from opiate dependence within the context of the UK drug strategy: methadone and Suboxone (buprenorphine-naloxone) patients compared. J Subst Abuse Treat.
McLellan AT, Arndt IO, Metzger DS, et al. (2010). The effects of psychosocial services in substance abuse treatment. JAMA.
McNeely J, Drucker E, Hartel D, et al. (2000). Office-based methadone prescribing: acceptance by inner-city practitioners in New York. J Urban Health.
Merrill JO, Jackson TR, Schulman BA, et al. (2005). Methadone medical maintenance in primary care. An implementation evaluation. J Gen Intern Med.
Metzger DS, Donnell D, Celentano DD, et al. (2015). Expanding substance use treatment options for HIV prevention with buprenorphine-naloxone: HIV Prevention Trials Network 058. J Acquir Immune Defic Syndr.
Meyer M, Benvenuto A, Howard D, et al. (2012). Development of a substance abuse program for opioid-dependent nonurban pregnant women improves outcome. J Addict Med.
Mills KL, Teesson M, Back SE, et al. (2012). Integrated exposure-based therapy for co-occurring posttraumatic stress disorder and substance dependence: a randomized controlled trial. JAMA.
Minozzi S, Amato L, Bellisario C, et al. (2014). Maintenance treatments for opiate -dependent adolescents. Cochrane Database Syst Rev.
Minozzi S, Amato L, Bellisario C, et al. (2014). Detoxification treatments for opiate dependent adolescents. Cochrane Database Syst Rev.
Minozzi S, Amato L, Vecchi S, et al. (2008). Maintenance agonist treatments for opiate dependent pregnant women. Cochrane Database Syst Rev.
Mintzer IL, Eisenberg M, Terra M, et al. (2007). Treating opioid addiction with buprenorphine-naloxone in community-based primary care settings. Ann Fam Med.
Miotto K. (2013). Primary care management of opioid dependence: the addition of CBT gives no extra benefit compared to standard physician management alone. Evid Based Ment Health.
Miotto K, Hillhouse M, Donovick R, et al. (2012). Comparison of buprenorphine treatment for opioid dependence in 3 settings. J Addict Med.
Miotto K, McCann MJ, Rawson RA, et al. (1997). Overdose, suicide attempts and death among a cohort of naltrexone-treated opioid addicts. Drug Alcohol Depend.
Mitchell SG, Gryczynski J, Schwartz RP, et al. (2015). Changes in Quality of Life following Buprenorphine Treatment: Relationship with Treatment Retention and Illicit Opioid Use. J Psychoactive Drugs.
Mitchell SG, Gryczynski J, Schwartz RP, et al. (2013). A randomized trial of intensive outpatient (IOP) vs. standard outpatient (OP) buprenorphine treatment for African Americans. Drug Alcohol Depend.
Mitchell SG, Kelly SM, Brown BS, et al. (2012). HIV sex-risk behaviors among in- versus out-of-treatment heroin-addicted adults. Am J Drug Alcohol Abuse.
Monte AA, Mandell T, Wilford BB, et al. (2009). Diversion of buprenorphine/naloxone coformulated tablets in a region with high prescribing prevalence. J Addict Dis.
Montoya ID, Gorelick DA, Preston KL, et al. (2004). Randomized trial of buprenorphine for treatment of concurrent opiate and cocaine dependence. Clin Pharmacol Ther.
Montoya ID, Schroeder JR, Preston KL, et al. (2005). Influence of psychotherapy attendance on buprenorphine treatment outcome. J Subst Abuse Treat.
Mooney ME, Poling J, Gonzalez G, et al. (2008). Preliminary study of buprenorphine and bupropion for opioid-dependent smokers. Am J Addict.
Moore BA, Fazzino T, Barry DT, et al. (2013). The Recovery Line: A pilot trial of automated, telephone-based treatment for continued drug use in methadone maintenance. J Subst Abuse Treat.
Moore BA, Fiellin DA, Barry DT, et al. (2007). Primary care office-based buprenorphine treatment: comparison of heroin and prescription opioid dependent patients. J Gen Intern Med.
Moore SK, Marsch LA, Badger GJ, et al. (2011). Improvement in psychopathology among opioid-dependent adolescents during behavioral-pharmacological treatment. J Addict Med.
Mullen L, Barry J, Long J, et al. (2012). A national study of the retention of Irish opiate users in methadone substitution treatment. Am J Drug Alcohol Abuse.
Murphy LS, Oros MT, Dorsey SG. (2014). The Baltimore Buprenorphine Initiative: understanding the role of buprenorphine in addressing heroin addiction in an urban-based community. J Addict Nurs.
Nahvi S, Blackstock O, Sohler NL, et al. (2014). Smoking cessation treatment among office-based buprenorphine treatment patients. J Subst Abuse Treat.
Najavits LM, Rosier M, Nolan AL, et al. (2007). A new gender-based model for women’s recovery from substance abuse: results of a pilot outcome study. Am J Drug Alcohol Abuse.
Neufeld K, Kidorf M, King V, et al. (2010). Using enhanced and integrated services to improve response to standard methadone treatment: changing the clinical infrastructure of treatment networks. J Subst Abuse Treat.
Neufeld K, King V, Peirce J, et al. (2008). A comparison of 1-year substance abuse treatment outcomes in community syringe exchange participants versus other referrals. Drug Alcohol Depend.
Neufeld KJ, Kidorf MS, Kolodner K, et al. (2008). A behavioral treatment for opioid-dependent patients with antisocial personality. J Subst Abuse Treat.
Neumann AM, Blondell RD, Azadfard M, et al. (2013). Primary care patient characteristics associated with completion of 6-month buprenorphine treatment. Addict Behav.
Ngo HT, Tait RJ, Arnold-Reed DE, et al. (2007). Mental health outcomes following naltrexone implant treatment for heroin-dependence. Prog Neuropsychopharmacol Biol Psychiatry.
Ngo HT, Tait RJ, Hulse GK. (2008). Comparing drug-related hospital morbidity following heroin dependence treatment with methadone maintenance or naltrexone implantation. Arch Gen Psychiatry.
Nielsen S, Hillhouse M, Thomas C, et al. (2013). A comparison of buprenorphine taper outcomes between prescription opioid and heroin users. J Addict Med.
Niveau G, Rougemont AL, La Harpe R. (2002). Methadone maintenance treatment, criminality and overdose-related deaths. An ecological study, 1983–1999. Eur J Public Health.
Nosyk B, Fischer B, Sun H, et al. (2014). High levels of opioid analgesic co-prescription among methadone maintenance treatment clients in British Columbia, Canada: results from a population-level retrospective cohort study. Am J Addict.
Nosyk B, Guh DP, Sun H, et al. (2011). Health related quality of life trajectories of patients in opioid substitution treatment. Drug Alcohol Depend.
Nosyk B, MacNab YC, Sun H, et al. (2009). Proportional hazards frailty models for recurrent methadone maintenance treatment. Am J Epidemiol.
Nosyk B, Sun H, Evans E, et al. (2012). Defining dosing pattern characteristics of successful tapers following methadone maintenance treatment: results from a population-based retrospective cohort study. Addiction.
Nunes EV, Rothenberg JL, Sullivan MA, et al. (2006). Behavioral therapy to augment oral naltrexone for opioid dependence: a ceiling on effectiveness?. Am J Drug Alcohol Abuse.
O’Connor PG, Oliveto AH, Shi JM, et al. (1996). A pilot study of primary-care-based buprenorphine maintenance for heroin dependence. Am J Drug Alcohol Abuse.
O’Connor PG, Oliveto AH, Shi JM, et al. (1998). A randomized trial of buprenorphine maintenance for heroin dependence in a primary care clinic for substance users versus a methadone clinic. Am J Med.
Ohlin L, Fridell M, Nyhlen A. (2015). Buprenorphine maintenance program with contracted work/education and low tolerance for non-prescribed drug use: a cohort study of outcome for women and men after seven years. BMC Psychiatry.
Oliver P, Keen J, Rowse G, et al. (2010). The effect of time spent in treatment and dropout status on rates of convictions, cautions and imprisonment over 5 years in a primary care-led methadone maintenance service. Addiction.
Ortner R, Jagsch R, Schindler SD, et al. (2004). Buprenorphine maintenance: office-based treatment with addiction clinic support. Eur Addict Res.
Otiashvili D, Kirtadze I, O’Grady KE, et al. (2012). Drug use and HIV risk outcomes in opioid-injecting men in the Republic of Georgia: behavioral treatment + naltrexone compared to usual care. Drug Alcohol Depend.
O’Toole J, Hambly R, Cox AM, et al. (2014). Methadone-maintained patients in primary care have higher rates of chronic disease and multimorbidity, and use health services more intensively than matched controls. Eur J Gen Pract.
Pan S, Jiang H, Du J, et al. (2015). Efficacy of Cognitive Behavioral Therapy on Opiate Use and Retention in Methadone Maintenance Treatment in China: A Randomised Trial. PLoS ONE.
Parmenter J, Mitchell C, Keen J, et al. (2013). Predicting biopsychosocial outcomes for heroin users in primary care treatment: a prospective longitudinal cohort study. Br J Gen Pract.
Parran TV, Adelman CA, Merkin B, et al. (2010). Long-term outcomes of office-based buprenorphine/naloxone maintenance therapy. Drug Alcohol Depend.
Perez de los Cobos J, Martin S, Etcheberrigaray A, et al. (2000). A controlled trial of daily versus thrice-weekly buprenorphine administration for the treatment of opioid dependence. Drug Alcohol Depend.
Perry AE, Neilson M, Martyn-St James M, et al. (2015). Pharmacological interventions for drug-using offenders. Cochrane Database Syst Rev.
Platt L, Reed J, Minozzi S, et al. (2016). Effectiveness of needle/syringe programmes and opiate substitution therapy in preventing HCV transmission among people who inject drugs. Cochrane Database Syst Rev.
Potter JS, Dreifuss JA, Marino EN, et al. (2015). The multi-site prescription opioid addiction treatment study: 18-month outcomes. J Subst Abuse Treat.
Preston KL, Silverman K, Umbricht A, et al. (1999). Improvement in naltrexone treatment compliance with contingency management. Drug Alcohol Depend.
Rabinowitz J, Cohen H, Tarrasch R, et al. (1997). Compliance to naltrexone treatment after ultra-rapid opiate detoxification: an open label naturalistic study. Drug Alcohol Depend.
Raisch DW, Campbell HM, Garnand DA, et al. (2012). Health-related quality of life changes associated with buprenorphine treatment for opioid dependence. Qual Life Res.
Rea F, Bell JR, Young MR, et al. (2004). A randomised, controlled trial of low dose naltrexone for the treatment of opioid dependence. Drug Alcohol Depend.
Reece AS. (2007). Psychosocial and treatment correlates of opiate free success in a clinical review of a naltrexone implant program. Subst Abuse Treat Prev Policy.
Reece AS. (2009). Comparative treatment and mortality correlates and adverse event profile of implant naltrexone and sublingual buprenorphine. J Subst Abuse Treat.
Reece AS. (2010). Favorable mortality profile of naltrexone implants for opiate addiction. J Addict Dis.
Resnick RB, Galanter M, Resnick E, et al. (2001). Buprenorphine treatment of heroin dependence (detoxification and maintenance) in a private practice setting. J Addict Dis.
Ritter AJ, Lintzeris N, Clark N, et al. (2003). A randomized trial comparing levo-alpha acetylmethadol with methadone maintenance for patients in primary care settings in Australia. Addiction.
Roberson CM. (2010). Outpatient opioid addiction treatment using buprenorphine. Ala Nurse.
Roberts J, Annett H, Hickman M. (2011). A systematic review of interventions to increase the uptake of opiate substitution therapy in injecting drug users. J Public Health (Oxf).
Roozen HG, Kerkhof AJ, van den Brink W. (2003). Experiences with an outpatient relapse program (community reinforcement approach) combined with naltrexone in the treatment of opioid-dependence: effect on addictive behaviors and the predictive value of psychiatric comorbidity. Eur Addict Res.
Rosenblum A, Joseph H, Fong C, et al. (2003). Prevalence and characteristics of chronic pain among chemically dependent patients in methadone maintenance and residential treatment facilities. JAMA.
Rosenthal RN, Ling W, Casadonte P, et al. (2013). Buprenorphine implants for treatment of opioid dependence: randomized comparison to placebo and sublingual buprenorphine/naloxone. Addiction.
Ross D, Lo F, McKim R, et al. (2008). A primary care/multidisciplinary harm reduction clinic including opiate bridging. Subst Use Misuse.
Rothenberg JL, Sullivan MA, Church SH, et al. (2002). Behavioral naltrexone therapy: an integrated treatment for opiate dependence. J Subst Abuse Treat.
Roux P, Villes V, Bry D, et al. (2008). Buprenorphine sniffing as a response to inadequate care in substituted patients: results from the Subazur survey in south-eastern France. Addict Behav.
Rowe TA, Jacapraro JS, Rastegar DA. (2012). Entry into primary care-based buprenorphine treatment is associated with identification and treatment of other chronic medical problems. Addict Sci Clin Pract.
Ruetsch C, Cacciola J, Tkacz J. (2010). A national study of a telephone support service for patients receiving office-based buprenorphine medication-assisted treatment: study feasibility and sample description. J Subst Abuse Treat.
Ruetsch C, Tkacz J, McPherson TL, et al. (2012). The effect of telephonic patient support on treatment for opioid dependence: outcomes at one year follow-up. Addict Behav.
Salsitz EA, Joseph H, Frank B, et al. (2000). Methadone medical maintenance (MMM): treating chronic opioid dependence in private medical practice--a summary report (1983–1998). Mt Sinai J Med.
Sigmon SC, Dunn KE, Saulsgiver K, et al. (2013). A randomized, double-blind evaluation of buprenorphine taper duration in primary prescription opioid abusers. JAMA Psychiatry.
Smyth BP, Fagan J, Kernan K. (2012). Outcome of heroin-dependent adolescents presenting for opiate substitution treatment. J Subst Abuse Treat.
Soeffing JM, Martin LD, Fingerhood MI, et al. (2009). Buprenorphine maintenance treatment in a primary care setting: outcomes at 1 year. J Subst Abuse Treat.
Sohler NL, Li X, Kunins HV, et al. (2010). Home- versus office-based buprenorphine inductions for opioid-dependent patients. J Subst Abuse Treat.
Soyka M, Apelt SM, Lieb M, et al. (2006). One-year mortality rates of patients receiving methadone and buprenorphine maintenance therapy: a nationally representative cohort study in 2694 patients. J Clin Psychopharmacol.
Soyka M, Trader A, Klotsche J, et al. (2012). Criminal behavior in opioid-dependent patients before and during maintenance therapy: 6-year follow-up of a nationally representative cohort sample. J Forensic Sci.
Soyka M, Zingg C. (2009). Feasability and safety of transfer from racemic methadone to (R)-methadone in primary care: clinical results from an open study. World J Biol Psychiatry.
Stein MD, Cioe P, Friedmann PD. (2005). Buprenorphine retention in primary care. J Gen Intern Med.
Stenbacka M, Leifman A, Romelsjo A. (1998). The impact of methadone on consumption of inpatient care and mortality, with special reference to HIV status. Subst Use Misuse.
Stenbacka M, Leifman A, Romelsjo A. (2003). The impact of methadone treatment on registered convictions and arrests in HIV-positive and HIV-negative men and women with one or more treatment periods. Drug Alcohol Rev.
Strain EC. (2003). Review: there is insufficient evidence for naltrexone maintenance treatment in opioid dependence. Evid Based Ment Health.
Strain EC, Stitzer ML, Liebson IA, et al. (1996). Buprenorphine versus methadone in the treatment of opioid dependence: self-reports, urinalysis, and addiction severity index. J Clin Psychopharmacol.
Strang J, Groshkova T, Uchtenhagen A, et al. (2015). Heroin on trial: systematic review and meta-analysis of randomised trials of diamorphine-prescribing as treatment for refractory heroin addiction. Br J Psychiatry.
Strang J, Sheridan J, Barber N. (1996). Prescribing injectable and oral methadone to opiate addicts: results from the 1995 national postal survey of community pharmacies in England and Wales. BMJ.
Strang J, Sheridan J, Hunt C, et al. (2005). The prescribing of methadone and other opioids to addicts: national survey of GPs in England and Wales. Br J Gen Pract.
Stumbo SP, Yarborough BJ, Janoff SL, et al. (2015). A Qualitative Analysis of Family Involvement in Prescribed Opioid Medication Monitoring among Individuals who have Experienced Opioid Overdoses. Substance abuse.
Sullivan LE, Chawarski M, O’Connor PG, et al. (2005). The practice of office-based buprenorphine treatment of opioid dependence: is it associated with new patients entering into treatment?. Drug Alcohol Depend.
Sullivan LE, Moore BA, Chawarski MC, et al. (2008). Buprenorphine/naloxone treatment in primary care is associated with decreased human immunodeficiency virus risk behaviors. J Subst Abuse Treat.
Sullivan LE, Moore BA, O’Connor PG, et al. (2010). The association between cocaine use and treatment outcomes in patients receiving office-based buprenorphine/naloxone for the treatment of opioid dependence. Am J Addict.
Sullivan SG, Wu Z, Cao X, et al. (2014). Continued drug use during methadone treatment in China: a retrospective analysis of 19,026 service users. J Subst Abuse Treat.
Sullivan SG, Wu Z, Detels R, et al. (2013). Time to first treatment interruption in the Chinese methadone maintenance treatment programme. Drug Alcohol Depend.
Sun HM, Li XY, Chow EP, et al. (2015). Methadone maintenance treatment programme reduces criminal activity and improves social well-being of drug users in China: a systematic review and meta-analysis. BMJ Open.
Tait RJ, Ngo HT, Hulse GK. (2008). Mortality in heroin users 3 years after naltrexone implant or methadone maintenance treatment. J Subst Abuse Treat.
Teesson M, Ross J, Darke S, et al. (2006). One year outcomes for heroin dependence: findings from the Australian Treatment Outcome Study (ATOS). Drug Alcohol Depend.
Terplan M, Lui S, Terplan M, et al. (2015). Psychosocial interventions for pregnant women in outpatient illicit drug treatment programs compared to other interventions. Cochrane Database Syst Rev.
Thirion X, Lapierre V, Micallef J, et al. (2002). Buprenorphine prescription by general practitioners in a French region. Drug Alcohol Depend.
Tucker TK, Ritter AJ. (2000). Naltrexone in the treatment of heroin dependence: A literature review. Drug Alcohol Rev.
Uosukainen H, Bell JS, Laitinen K, et al. (2013). First insights into community pharmacy based buprenorphine-naloxone dispensing in Finland. Int J Drug Policy.
van Brussel G. (1995). Methadone treatment by general practitioners in Amsterdam. Bull N Y Acad Med.
Van Doren BA, Foulks-Rodriguez KA, Yarborough W. (2015). Opioid Addiction Treatment Using Buprenorphine-Naloxone In A Community-Based Internal Medicine Practice. J Okla State Med Assoc.
Vidal-Trecan G, Varescon I, Nabet N, et al. (2003). Intravenous use of prescribed sublingual buprenorphine tablets by drug users receiving maintenance therapy in France. Drug Alcohol Depend.
Vidjak N. (2003). Treating heroin addiction: comparison of methadone therapy, hospital therapy without methadone, and therapeutic community. Croat Med J.
Waal H, Brekke M, Clausen T, et al. (2012). General practitioners’ views on drug-assisted rehabilitation. Tidsskr Nor Laegeforen.
Walley AY, Cheng DM, Pierce CE, et al. (2012). Methadone dose, take home status, and hospital admission among methadone maintenance patients. J Addict Med.
Wang PW, Wu HC, Yen CN, et al. (2012). Change in quality of life and its predictors in heroin users receiving methadone maintenance treatment in Taiwan: an 18-month follow-up study. Am J Drug Alcohol Abuse.
Weiss RD. (2014). Behavioural treatment combined with buprenorphine does not reduce opioid use compared with buprenorphine alone. Evid Based Ment Health.
Weiss RD, Griffin ML, Potter JS, et al. (2014). Who benefits from additional drug counseling among prescription opioid-dependent patients receiving buprenorphine-naloxone and standard medical management?. Drug Alcohol Depend.
Whitley SD, Kunins HV, Arnsten JH, et al. (2007). Colocating buprenorphine with methadone maintenance and outpatient chemical dependency services. J Subst Abuse Treat.
Wisniewski AM, Dlugosz MR, Blondell RD. (2013). Reimbursement and practice policies among providers of buprenorphine-naloxone treatment. Substance abuse.
Wittchen HU, Apelt SM, Buhringer G, et al. (2005). Buprenorphine and methadone in the treatment of opioid dependence: methods and design of the COBRA study. Int J Methods Psychiatr Res.
Wittchen HU, Apelt SM, Soyka M, et al. (2008). Feasibility and outcome of substitution treatment of heroin-dependent patients in specialized substitution centers and primary care facilities in Germany: a naturalistic study in 2694 patients. Drug Alcohol Depend.
Wolff K, Hay AW, Vail A, et al. (1996). Non-prescribed drug use during methadone treatment by clinic- and community-based patients. Addiction.
Woody GE, Poole SA, Subramaniam G, et al. (2008). Extended vs short-term buprenorphine-naloxone for treatment of opioid-addicted youth: a randomized trial. JAMA.
Wright NM, Sheard L, Adams CE, et al. (2011). Comparison of methadone and buprenorphine for opiate detoxification (LEEDS trial): a randomised controlled trial. Br J Gen Pract.
Wright NM, Sheard L, Tompkins CN, et al. (2007). Buprenorphine versus dihydrocodeine for opiate detoxification in primary care: a randomised controlled trial. BMC Fam Pract.
Yarborough BJ, Stumbo SP, McCarty D, et al. (2016). Methadone, buprenorphine and preferences for opioid agonist treatment: A qualitative analysis. Drug Alcohol Depend.
Zador D, Sunjic S. (2000). Deaths in methadone maintenance treatment in New South Wales, Australia 1990–1995. Addiction.
Zanis DA, Woody GE. (1998). One-year mortality rates following methadone treatment discharge. Drug Alcohol Depend.
Zhang L, Chow EP, Zhuang X, et al. (2013). Methadone maintenance treatment participant retention and behavioural effectiveness in China: a systematic review and meta-analysis. PLoS ONE.
Zhou K, Zhuang G. (2014). Retention in methadone maintenance treatment in mainland China, 2004–2012: a literature review. Addict Behav.
Zickler P. (2006). Buprenorphine plus behavioral therapy is effective for adolescents with opioid addiction. Nida Notes.