# Appendix D Included Studies List

## Trials

Carrieri PM, Michel L, Lions C, et al. (2014). Methadone induction in primary care for opioid dependence: a pragmatic randomized trial (ANRS Methaville). PLoS ONE.
Christensen DR, Landes RD, Jackson L, et al. (2014). Adding an Internet-delivered treatment to an efficacious treatment package for opioid dependence. J Consult Clin Psychol.
D’Onofrio G, O’Connor PG, Pantalon MV, et al. (2015). Emergency department-initiated buprenorphine/naloxone treatment for opioid dependence: a randomized clinical trial. JAMA.
Fiellin DA, O’Connor PG, Chawarski M, et al. (2001). Methadone maintenance in primary care: a randomized controlled trial. JAMA.
Fiellin DA, Pantalon MV, Pakes JP, et al. (2002). Treatment of heroin dependence with buprenorphine in primary care. Am J Drug Alcohol Abuse.
Fiellin DA, Pantalon MV, Chawarski MC, et al. (2006). Counseling plus buprenorphine-naloxone maintenance therapy for opioid dependence. N Engl J Med.
Fiellin DA, Barry DT, Sullivan LE, et al. (2013). A randomized trial of cognitive behavioral therapy in primary care-based buprenorphine. Am J Med.
Fudala PJ, Bridge TP, Herbert S, et al. (2003). Office-based treatment of opiate addiction with a sublingual-tablet formulation of buprenorphine and naloxone. N Engl J Med.
Galanter M, Dermatis H, Glickman L, et al. (2004). Network therapy: decreased secondary opioid use during buprenorphine maintenance. J Subst Abuse Treat.
King VL, Kidorf MS, Stoller KB, et al. (2006). A 12-month controlled trial of methadone medical maintenance integrated into an adaptive treatment model. J Subst Abuse Treat.
Liebschutz JM, Crooks D, Herman D, et al. (2014). Buprenorphine treatment for hospitalized, opioid-dependent patients: a randomized clinical trial. JAMA Intern Med.
Lintzeris N, Ritter A, Panjari M, et al. (2004). Implementing buprenorphine treatment in community settings in Australia: experiences from the Buprenorphine Implementation Trial. Am J Addict.
Lucas GM, Chaudhry A, Hsu J, et al. (2010). Clinic-based treatment of opioid-dependent HIV-infected patients versus referral to an opioid treatment program: A randomized trial. Ann Intern Med.
Moore BA, Barry DT, Sullivan LE, et al. (2012). Counseling and directly observed medication for primary care buprenorphine maintenance: a pilot study. J Addict Med.
Roux P, Michel L, Cohen J, et al. (2012). Methadone induction in primary care (ANRS-Methaville): a phase III randomized intervention trial. BMC Public Health.
Sullivan LE, Barry D, Moore BA, et al. (2006). A trial of integrated buprenorphine/naloxone and HIV clinical care. Clin Infect Dis.
Tetrault JM, Moore BA, Barry DT, et al. (2012). Brief versus extended counseling along with buprenorphine/naloxone for HIV-infected opioid dependent patients. J Subst Abuse Treat.
Weiss RD, Potter JS, Fiellin DA, et al. (2011). Adjunctive counseling during brief and extended buprenorphine-naloxone treatment for prescription opioid dependence: a 2-phase randomized controlled trial. Arch Gen Psychiatry.
Weiss RD, Potter JS, Griffin ML, et al. (2015). Long-term outcomes from the National Drug Abuse Treatment Clinical Trials Network Prescription Opioid Addiction Treatment Study. Drug Alcohol Depend.

## Systematic Reviews

Amato L, Minozzi S, Davoli M, et al. (2011). Psychosocial combined with agonist maintenance treatments versus agonist maintenance treatments alone for treatment of opioid dependence. Cochrane Database Syst Rev.
Ferri M, Minozzi S, Bo A, et al. (2013). Slow-release oral morphine as maintenance therapy for opioid dependence. Cochrane Database Syst Rev.
Gowing L, Farrell MF, Bornemann R, et al. (2011). Oral substitution treatment of injecting opioid users for prevention of HIV infection. Cochrane Database Syst Rev.
Lobmaier P, Kornor H, Kunoe N, et al. (2008). Sustained-release naltrexone for opioid dependence. Cochrane Database Syst Rev.
Mattick RP, Breen C, Kimber J, et al. (2009). Methadone maintenance therapy versus no opioid replacement therapy for opioid dependence. Cochrane Database Syst Rev.
Mattick RP, Breen C, Kimber J, et al. (2014). Buprenorphine maintenance versus placebo or methadone maintenance for opioid dependence. Cochrane Database Syst Rev.
Minozzi S, Amato L, Davoli M. (2009). Maintenance treatments for opiate dependent adolescent. Cochrane Database Syst Rev.
Minozzi S, Amato L, Vecchi S, et al. (2011). Oral naltrexone maintenance treatment for opioid dependence. Cochrane Database Syst Rev.
Minozzi S, Amato L, Bellisario C, et al. (2013). Maintenance agonist treatments for opiate-dependent pregnant women. Cochrane Database Syst Rev.
Nielsen S, Larance B, Degenhardt L, et al. (2016). Opioid agonist treatment for pharmaceutical opioid dependent people. Cochrane Database Syst Rev.
Rahimi-Movaghar A, Amin-Esmaeili M, Hefazi M, et al. (2013). Pharmacological therapies for maintenance treatments of opium dependence. Cochrane Database Syst Rev.