# Appendix B Search Strategies for Guiding Question 3

## Database: Ovid MEDLINE

1. exp Opiate Substitution Treatment
2. exp Opioid-Related Disorders/dt, pc, px, rh, th
3. methadone.mp. or exp Methadone
4. buprenorphine.mp. or Buprenorphine
5. naltrexone.mp. or Naltrexone
6. suboxone.mp.
7. 3 or 4 or 5 or 6
8. 2 and 7
9. (medicat* adj3 assist* adj3 (treat* or therap* or regimen* or interven* or program*)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
10. ((opiate* or opioid* or narcotic*) adj2 (substitut* or replac* or maint*) adj2 (treatment* or therap* or regimen* or program* or interven*)).ti,ab.
11. 9 or 10
12. 2 and 11
13. 1 or 8 or 12
14. limit 13 to english language
15. exp Comprehensive Health Care/
16. exp Community Health Services/
17. exp Outpatients/
18. exp Ambulatory Care/
19. exp Ambulatory Care Facilities/
20. exp General Practice/
21. general practitioners/or physicians, family/or physicians, primary care/
22. exp Health Services Accessibility/
23. 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22
24. (((primary or ambulatory) adj3 care) or ((family or general) adj3 (medicine or practice* or physician* or doctor* or practitioner* or provider*)) or outpatient* or ((communit* or comprehensiv*) adj3 (health* or care))).mp.
25. (rural* or underserv* or frontier* or (geograph* adj3 (isolat* or remot*))).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
26. 24 or 25
27. 23 or 26
28. 14 and 27
29. limit 28 to yr="2005 -Current"
30. limit 28 to yr="1902 – 2004"
31. limit 14 to systematic reviews
32. limit 14 to (controlled clinical trial or guideline or randomized controlled trial)
33. exp epidemiologic study/
34. 14 and 33
35. Comparative Study/
36. 14 and 35
37. exp "Outcome and Process Assessment (Health Care)"/
38. 14 and 37
39. mo.fs.
40. exp Death/
41. exp Vital Statistics/
42. 39 or 40 or 41
43. 14 and 42
44. exp Evaluation Studies as Topic/
45. 14 and 44
46. exp "costs and cost analysis"/
47. 14 and 46
48. exp Sociological Factors/
49. 14 and 48
50. exp quality of life/
51. 14 and 50
52. exp health behavior/
53. 14 and 52
54. exp attitude to health/
55. 14 and 54
56. 31 or 32 or 34 or 36 or 38 or 43 or 45 or 47 or 49 or 51 or 53 or 55
57. 28 or 56

## Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. [exp Opiate Substitution Treatment/]
2. [exp Opioid-Related Disorders/dt, pc, px, rh, th]
3. methadone.mp. or exp Methadone/
4. buprenorphine.mp. or Buprenorphine/
5. naltrexone.mp. or Naltrexone/
6. suboxone.mp.
7. 3 or 4 or 5 or 6
8. 2 and 7
9. (medicat* adj3 assist* adj3 (treat* or therap* or regimen* or interven* or program*)).mp.
10. ((opiate* or opioid* or narcotic*) adj2 (substitut* or replac* or maint*) adj2 (treatment* or therap* or regimen* or program* or interven*)).ti,ab.
11. 9 or 10
12. 1 or 8 or 11

## Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. exp Opiate Substitution Treatment/
2. exp Opioid-Related Disorders/dt, pc, px, rh, th
3. methadone.mp. or exp Methadone/
4. buprenorphine.mp. or Buprenorphine/
5. naltrexone.mp. or Naltrexone/
6. suboxone.mp.
7. 3 or 4 or 5 or 6
8. 2 and 7
9. (medicat* adj3 assist* adj3 (treat* or therap* or regimen* or interven* or program*)).mp.
10. ((opiate* or opioid* or narcotic*) adj2 (substitut* or replac* or maint*) adj2 (treatment* or therap* or regimen* or program* or interven*)).ti,ab.
11. 9 or 10
12. 1 or 8 or 11

## Database: PsycINFO

1. exp opiates/
2. exp drug rehabilitation/
3. exp drug dependency/
4. 2 or 3
5. exp drug therapy/
6. exp methadone maintenance/
7. methadone.mp. or exp Methadone/
8. buprenorphine.mp. or Buprenorphine/
9. naltrexone.mp. or Naltrexone/
10. suboxone.mp.
11. 5 or 6 or 7 or 8 or 9 or 10
12. 1 and 4 and 11
13. (medicat* adj3 assist* adj3 (treat* or therap* or regimen* or interven* or program*)).mp.
14. ((opiate* or opioid* or narcotic*) adj2 (substitut* or replac* or maint*) adj2 (treatment* or therap* or regimen* or program* or interven*)).ti,ab.
15. 13 or 14
16. 1 and 4 and 15
17. 12 or 16
18. limit 17 to english language
19. exp Primary Health Care/
20. exp community services/
21. exp Outpatients/
22. exp outpatient treatment/
23. exp Maintenance Therapy/
24. exp Ambulatory Care/
25. exp Ambulatory Care Facilities/
26. exp General Practitioners/
27. exp Family Medicine/
28. exp Family Physicians/
29. exp Treatment Barriers/
30. exp health disparities/
31. exp health care utilization/
32. 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31
33. (((primary or ambulatory) adj3 care) or ((family or general) adj3 (medicine or practice* or physician* or doctor* or practitioner* or provider*)) or outpatient* or ((communit* or comprehensiv*) adj3 (health* or care))).mp.
34. (rural* or underserv* or frontier* or (geograph* adj3 (isolat* or remot*))).mp.
35. 33 or 34
36. 32 or 35
37. 18 and 36
38. limit 18 to systematic reviews
39. exp treatment outcomes/or exp treatment effectiveness evaluation/
40. 18 and 39
41. exp "Death and Dying"/
42. exp mortality rate/
43. 41 or 42
44. 18 and 43
45. exp "costs and cost analysis"/
46. 18 and 45
47. exp Sociocultural Factors/
48. exp socioeconomic status/
49. 47 or 48
50. 18 and 49
51. exp quality of life/
52. 18 and 51
53. exp health behavior/
54. 18 and 53
55. exp attitudes/
56. 18 and 55
57. 38 or 40 or 44 or 46 or 50 or 52 or 54 or 56
58. 37 or 57

## CINAHL

S1 (MH "Substance Use Disorders+")
S2 (MH "Narcotics+")
S3 S1 AND S2
S4 "methadone"
S5 "buprenorphine"
S6 "naltrexone"
S7 suboxone
S8 S4 OR S5 OR S6 OR S7
S9 S1 AND S8
S10 (medicat* n3 assist* n3 (treat* or therap* or regimen* or interven* or program*))
S11 ((opiate* or opioid* or narcotic*) n2 (substitut* or replac* or maint*) n2 (treatment* or therap* or regimen* or program* or interven*))
S12 S10 OR S11
S13 S1 AND S12
S14 S3 OR S9 OR S13
S15 S3 OR S9 OR S13
S16 (MH "Primary Health Care")
S17 (MH "Community Health Services+")
S18 (MH "Outpatients") OR (MH "Outpatient Service") OR (MH "Ambulatory Care Facilities+")
S19 (MH "Family Practice")
S20 (MH "Physicians, Family")
S21 (MH "Health Services Accessibility+")
S22 S16 OR S17 OR S18 OR S19 OR S20 OR S21
S23 (((primary or ambulatory) n3 care) or ((family or general) n3 (medicine or practice* or physician* or doctor* or practitioner* or provider*)) or outpatient* or ((communit* or comprehensiv*) n3 (health* or care)))
S24 (rural* or underserv* or frontier* or (geograph* n3 (isolat* or remot*)))
S25 S23 OR S24
S26 S22 OR S25
S27 S15 AND S26
S28 (MH "Systematic Review")
S29 (MH "Meta Analysis")
S30 (MH "Practice Guidelines") OR (MH "Guideline Adherence")
S31 (MH "Randomized Controlled Trials")
S32 (MH "Epidemiological Research+")
S33 (MH "Prospective Studies+")
S34 S28 OR S29 OR S30 OR S31 OR S32 OR S33
S35 S15 AND S34
S36 (MH "Outcomes (Health Care)+")
S37 (MH "Vital Statistics+")
S38 (MH "Evaluation Research+")
S39 (MH "Costs and Cost Analysis+")
S40 (MH "Socioeconomic Factors+")
S41 (MH "Cultural Values")
S42 (MH "Quality of Life+")
S43 (MH "Quality-Adjusted Life Years")
S44 (MH "Health Behavior+")
S45 (MH "Attitude+")
S46 S36 OR S37 OR S38 OR S42 OR S43
S47 S15 AND S46
S48 S15 AND S46
S49 S15 AND S34
S50 s48 NOT s49

## SocINDEX

S1 (MH "Substance Use Disorders+")
S2 (MH "Narcotics+")
S3 S1 AND S2
S4 "methadone"
S5 "buprenorphine"
S6 "naltrexone"
S7 suboxone
S8 S4 OR S5 OR S6 OR S7
S9 S1 AND S8
S10 (medicat* n3 assist* n3 (treat* or therap* or regimen* or interven* or program*))
S11 ((opiate* or opioid* or narcotic*) n2 (substitut* or replac* or maint*) n2 (treatment* or therap* or regimen* or program* or interven*))
S12 S10 OR S11
S13 S9 OR S12