# Appendix A Sample Questions for Key Informants

Key Informant Perspective | Sample Questions
Researchers and Clinicians (including Professional Societies and Organizations) | Guiding Questions 1, 2, and 4. In addition:; 1. What outcomes should be prioritized?; 2. In your experience, what MAT models of care have been particularly successful and why?; 3. Are there models of care that are particularly suited (e.g., feasibility, applicability) for rural or other underserved settings?; 4. How would you categorize the components of MAT models of care?; 5. What MAT models of care components are most critical for effectiveness?; 6. What are barriers to implementation of MAT in primary care settings?; 7. What are specific barriers to implementation of community-based psychosocial programs in MAT?; 8. How could barriers to implementation be overcome?; 9. Are you aware of new or innovative models of care that warrant additional research?; 10. What are key research needs to understand effectiveness and implementation of MAT models of care?; 11. What types of study designs would be useful for studying new or innovative MAT models of care?; 12. What is a meaningful length of followup?; 13. Are there specific areas related to effectiveness or implementation of MAT models of care that have been sufficiently studied to warrant a systematic evidence review?
Health Policy and Implementation Arenas | 1. What outcomes of MAT are important from a health policy/payer perspective?; 2. What policies do payers put in place to influence use of MAT for treatment of opioid use disorder?; 3. How are decisions to cover or implement MAT made at a policy level or at an institutional/clinical setting level?; 4. What are some research questions about MAT that you would like answered to inform policy and implementation decisions?; 5. Are you considering new policies to improve the use of MAT, particularly in primary care, including rural or other underserved populations?; 6. What are cost and/or economic efficiency considerations that impact diffusion, decision-making, and/or conceptual thinking around MAT?
Patient Perspective | 1. What values do patients place on various non-substance-use-related outcomes and how do patients weigh trade-offs related to different pharmacological and non-pharmacological approaches?; 2. What factors or themes are most important to patients receiving MAT?; 3. What components of MAT are important for patients to know, that they may not be aware of?; 4. What common experiences do patients in MAT programs describe?; 5. Should the use of MAT programs be expanded; and if so, what settings for patients are most amenable to the implementation of MAT?; 6. What barriers do patients experience in obtaining MAT?; 7. What suggestions do patients have for improving MAT models of care?; 8. What are ethical, privacy, equity, or cost considerations that impact patient’s use of MAT?

MAT = medication-assisted treatment