# References

1 Institute of Medicine. (1999). To Err is Human: Building a Safer Health System.
2 Brennan TA, Leape LL. (1991). Adverse events, negligence in hospitalized patients: results from the Harvard Medical Practice Study. Perspect Healthc Risk Manage.
3 Gandhi TK, Weingart SN, Borus J, et al. (2003). Adverse drug events in ambulatory care. N Engl J Med.
4 Sarkar U, Karter AJ, Liu JY, et al. (2010). Hypoglycemia is more common among type 2 diabetes patients with limited health literacy: the Diabetes Study of Northern California (DISTANCE). J Gen Intern Med.
5 Institute of Medicine. (2004). Patient Safety: Achieving a New Standard for Care.
6 Furukawa MF, King J, Patel V, et al. (2014). Despite substantial progress In EHR adoption, health information exchange and patient engagement remain low in office settings. Health Aff (Millwood).
7 Linzer M, Baier Manwell L, Mundt M, et al. (2005). Organizational Climate, Stress, and Error in Primary Care: The MEMO Study. Henriksen K, Battles JB, Marks ES, Lewin DI, editors. Advances in Patient Safety: From Research to Implementation (Volume 1: Research Findings).
8 Sarkar U. (2014). Patient Safety in Outpatient Care. Agrawal A, editor. Patient Safety: A Comprehensive Guide.
9 Lorincz CY, Drazen E, Sokol PE, et al. (2011). Research in Ambulatory Patient Safety 2000–2010: A 10-Year Review.
10 Sarkar U, Wachter RM, Schroeder SA, et al. (2009). Refocusing the lens: patient safety in ambulatory chronic disease care. Jt Comm J Qual Patient Saf.
11 Shekelle PG, Wachter RM, Pronovost PJ, et al. (2013). Making Health Care Safer II: An Updated Critical Analysis of the Evidence for Patient Safety Practices.
12 Spickard A, Gabbe SG, Christensen JF. (2002). Mid-career burnout in generalist and specialist physicians. JAMA.
13 National Center for Emerging and Zoonotic Infectious Diseases. (2014). Guide to Infection Prevention for Outpatient Settings: Minimum Expectations for Safe Care.
14 Armstrong EP, Wang SM, Hines LE, et al. (2014). Prescriber perceptions of a near real-time fax alert program for potential drug-drug interactions. J Manag Care Spec Pharm.
15 Bhardwaja B, Carroll NM, Raebel MA, et al. (2011). Improving prescribing safety in patients with renal insufficiency in the ambulatory setting: the Drug Renal Alert Pharmacy (DRAP) program. Pharmacotherapy.
16 Boyle TA, Ho C, Mackinnon NJ, et al. (2013). Safety implications of standardized continuous quality improvement programs in community pharmacy. J Pharm Pract.
17 Bundy DG, Marsteller JA, Wu AW, et al. (2012). Electronic health record-based monitoring of primary care patients at risk of medication-related toxicity. Jt Comm J Qual Patient Saf.
18 Collins CM, Elsaid KA. (2011). Using an enhanced oral chemotherapy computerized provider order entry system to reduce prescribing errors and improve safety. Int J Qual Health Care.
19 Gabe ME, Murphy F, Davies GA, et al. (2014). Medication monitoring in a nurse-led respiratory outpatient clinic: pragmatic randomised trial of the West Wales Adverse Drug Reaction Profile. PLoS One.
20 Glassman PA, Belperio P, Lanto A, et al. (2007). The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc.
21 Griesbach S, Lustig A, Malsin L, et al. (2015). Best practices: an electronic drug alert program to improve safety in an accountable care environment. J Manag Care Spec Pharm.
22 Harrison J, Shaw JP, Harrison JE. (2015). Anticoagulation management by community pharmacists in New Zealand: an evaluation of a collaborative model in primary care. Int J Pharm Pract.
23 Hsu CC, Chou CY, Chou CL, et al. (2014). Impact of a warning CPOE system on the inappropriate pill splitting of prescribed medications in outpatients. PLoS One.
24 Kansagra A, Linden E. (2011). Systematic Tracking and Analysis of Admissions for Chemotherapy Toxicity Inform Quality Improvement Efforts, Leading to Reduced Toxicity Risk. Service Delivery Innovation Profile.
25 Lau B, Overby CL, Wirtz HS, et al. (2013). The association between use of a clinical decision support tool and adherence to monitoring for medication-laboratory guidelines in the ambulatory setting. Appl Clin Inform.
26 Lukazewski A, Mikula B, Servi A, et al. (2012). Evaluation of a web-based tool in screening for medication-related problems in community-dwelling older adults. Consult Pharm.
27 Lopez-Picazo JJ, Ruiz JC, Sanchez JF, et al. (2011). A randomized trial of the effectiveness and efficiency of interventions to reduce potential drug interactions in primary care. Am J Med Qual.
28 Matheny ME, Sequist TD, Seger AC, et al. (2008). A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc.
29 Palen TE, Raebel M, Lyons E, et al. (2006). Evaluation of laboratory monitoring alerts within a computerized physician order entry system for medication orders. Am J Manag Care.
30 Raebel MA, Lyons EE, Chester EA, et al. (2005). Improving laboratory monitoring at initiation of drug therapy in ambulatory care: a randomized trial. Arch Intern Med.
31 Raebel MA, Chester EA, Newsom EE, et al. (2006). Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy.
32 Raebel MA, Charles J, Dugan J, et al. (2007). Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc.
33 Raebel MA, Carroll NM, Kelleher JA, et al. (2007). Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc.
34 Ryan GJ, Caudle JM, Rhee MK, et al. (2013). Medication reconciliation: comparing a customized medication history form to a standard medication form in a specialty clinic (CAMPII 2). J Patient Saf.
35 Singh R, Anderson D, McLean-Plunkett E, et al. (2012). IT-enabled systems engineering approach to monitoring and reducing ADEs. Am J Manag Care.
36 Smith DH, Perrin N, Feldstein A, et al. (2006). The impact of prescribing safety alerts for elderly persons in an electronic medical record: an interrupted time series evaluation. Arch Intern Med.
37 Stock R. (2008). Reconciliation of Patient and Provider Medication Lists Reduces Discrepancies and Enhances Medication Safety in Physician Clinics. Archived Service Delivery Innovation Profile.
38 Tanner C, Gans D, White J, et al. (2015). Electronic health records and patient safety: co-occurrence of early EHR implementation with patient safety practices in primary care settings. Appl Clin Inform.
39 Touchette DR, Masica AL, Dolor RJ, et al. (2012). Safety-focused medication therapy management: a randomized controlled trial. J Am Pharm Assoc (2003).
40 Wessell AM, Ornstein SM, Jenkins RG, et al. (2013). Medication Safety in Primary Care Practice: results from a PPRNet quality improvement intervention. Am J Med Qual.
41 Willis JS, Hoy RH, Jenkins WD. (2011). In-home medication reviews: a novel approach to improving patient care through coordination of care. J Community Health.
42 Stewart AL, Lynch KJ. (2012). Identifying discrepancies in electronic medical records through pharmacist medication reconciliation. J Am Pharm Assoc (2003).
43 Varkey P, Cunningham J, Bisping DS. (2007). Improving medication reconciliation in the outpatient setting. Jt Comm J Qual Patient Saf.
44 National Patient Safety Foundation. (2015). Free From Harm: Accelerating Patient Safety Improvement Fifteen Years after To Err is Human (Report of an Expert Panel Convened by The National Patient Safety Foundation).
45 Balogh EP, Miller BT, Ball R, et al. (2015). Improving Diagnosis in Health Care.
46 Wachter RM. (2010). Patient safety at ten: unmistakable progress, troubling gaps. Health Aff (Millwood).
47 Budnitz DS, Layde PM. (2007). Outpatient drug safety: new steps in an old direction. Pharmacoepidemiol Drug Saf.