# Methods

## Overview

This Technical Brief integrates insights from discussions with Key Informants (KIs) with information extracted from the published literature and grey literature. Both KI discussions and literature scan were used to respond to guiding questions 1 and 2. A protocol for the conduct of this work was developed and filed with the Agency for Healthcare Research and Quality (http://effectivehealthcare.ahrq.gov/ehc/products/622/2104/ambulatory-safety-protocol-150724.pdf).

## Key Informant Discussions

We identified eight KIs from major stakeholder groups such as developers of PSPs, policy makers, persons overseeing health plan or organization safety, and including a patient advocate. Key Informants were identified by a group process involving the project team members and the Task Order Officer. Due to government regulations, the number of KIs was limited to nine non-federal participants.

In order to help answer guiding question 1, before conducting the interviews the project team evaluated the 41 PSPs that were included in the Making Health Care Safer (MHCS) II report^11^ and classified them into one of three categories:

- PSPs with a strong analogy to ambulatory care safety
- PSPs not relevant to ambulatory care
- PSPs with a “partial analogy” to ambulatory care

We also asked the project team and the Task Order Officer for input on any other practices that were not covered in MHCS II. This resulted in a list of 55 topics for which we would seek input from our KIs using an online questionnaire.

After the completion of the online questionnaire, we then scheduled teleconferences with our KIs. We sent the KIs the guiding questions, the protocol, and the list of included/excluded safety practices, and the following list of questions:

1. Are there important PSPs or targets left off the list of includes (in “PSP Survey Results”)? Things on the list you would recommend dropping?
2. Do you have any information on organizational models of care that promote patient safety?
3. If you were in charge of the government agency responsible for funding research on patient safety, what is the most important, or the most 3 important, topics for which you would want to see proposals?
4. What are the big categories of patient safety problems, in terms of importance? For some or all of these, we'll ask you to flesh them out a bit in terms of the types of problems and the types of interventions that you think have promise.
5. When you think about patient safety in outpatient settings, what keeps you up at night?

The teleconferences were moderated by the lead investigator and included other members of the project team and, when available, the Task Order Officer (TOO). The discussion was informal while still asking for specific answers to each of the questions.

### Analysis of Discussions

These KI teleconferences were audio recorded and transcribed with verbal consent from all participants. We reviewed the transcripts and identified themes inductively using open coding. One team member conducted initial coding, with a second team member reviewing codes. The team arrived at final themes through discussion and consensus. Although we had reached thematic saturation by the third discussion, we completed interviews with all KIs as pre-specified in our protocol. The summaries of these teleconferences can be found in Appendix B.

## Literature Scan Search Strategy

We conducted searches in Medline (PubMed) from 2000 to August 11, 2015. In addition, we searched for grey literature from AHRQ Patient Safety Network (PSNet), the AHRQ Innovations Exchange, Institute of Medicine (IOM), the Joint Commission website, the Institute for Safe Medication Practices, Patient Safety Quality Healthcare, and the Pennsylvania Patient Safety Authority Site (PA-PSRS). A separate search was conducted for each of the included PSPs. The full search methodology by topic can be found in Appendix A.

## Literature Scan Eligibility Criteria

Titles and abstracts were screened by one reviewer to identify studies meeting the following criteria:

1. Hypothesis-testing evaluation of a patient safety intervention
2. In ambulatory care
3. Targeted at safety
4. Reports a safety outcome
5. In a high income country, since the types of safety problems and patient/provider characteristics are probably context-specific.

Articles could have had more than one reason for exclusion, but only one was coded, and a hierarchy for exclusion reasons was not applied. Rather, the first obvious exclusion reason was chosen. Also, studies might appear in one particular PSP search but might be applicable for a different topic, for example a study might appear in a search about “monitoring” but consist of a pharmacist-led intervention to improve medication safety. On full text screening, studies meeting inclusion criteria were coded according to the actual PSP evaluated, and not the search from which it was identified.

There were 10 topics (diagnostic errors, health literacy, infection control, multimorbidity, patient engagement, pharmacists' role, radiation exposure, referrals, tracking test results, and workforce) for which our standard search retrieved large numbers of titles (758-3,022). In order to perform the literature scan within the timeframe and resources of the project, we developed an alternative search strategy for these 10 topics that reduced the number of titles by requiring the word “safety” be included in the title or abstract, OR the study was published in a leading general interest medical journal OR in a leading specialty journal for patient safety. We validated this “reduced titles” strategy by comparing titles selected thus to a 10% sample of the full search titles for the first three such topics, on patient engagement, the workforce, and infection control. No studies meeting inclusion criteria were missed using the “reduced titles” search. We thus concluded that for this literature scan this was an acceptable method for estimating the number of available studies in those topics.

Abstracts potentially meeting these inclusion criteria had full text articles retrieved and assessed by one reviewer. Studies included at this stage were then classified by:

- The patient safety target or practice
- The study design, with the categories Systematic Review, Randomized Controlled Trial, or Other Hypothesis-Testing Study.
- Whether the intervention was tested in a single setting (single office-based setting or plan) or whether it was tested in multiple settings. Studies tested in multiple sites within a health care delivery system that shares characteristics across sites, such as Kaiser or the Veteran Affairs, were considered to be equivalent to “single site” implementations.
- Data from the title and abstract and full text screening were tabulated for ease of comparison.

Details about the inclusion and exclusion criteria for some specific recurring circumstances are explained below:

1. Hypothesis-testing studies included statistical testing of outcomes between two or more comparison groups. Studies reporting only descriptive results of implementation of an intervention were not included (for example, we did not include studies of the implementation of an intervention, such as medication reconciliation, that reported the proportions of patients who had certain kinds of reconciliations performed). Systematic reviews were identified by their use of that word in their title or by following the basic methods of systematic reviews (such as presenting the search strategy, the flow of titles and abstracts leading to articles meeting the eligibility criteria, and the inclusion of evidence tables).
2. Ambulatory care included office-based care only. Studies set in the Emergency Department were considered to be closer to hospital-based care than ambulatory care and were, in general, not included. Studies set in hemodialysis centers were not included, while studies set in free-standing chemotherapy centers were included. Studies of surgical procedures requiring an operating room were not included, even though the care was delivered in an ambulatory surgery center. Studies of labor and delivery were excluded.
3. Safety outcomes were, in general, defined similar to how they are defined for hospital- based patient safety: they had to be a result of the care given, and not a part of the natural history of disease. Medication adherence was considered a quality outcome and not a safety outcome. Hospital readmission was considered a safety outcome.
4. Interventions whose main target was to increase a process were excluded, unless that process was linked to an outcome. For example, interventions aimed at increasing the use of medication reconciliation were excluded unless there was also an assessment of potential or actual adverse drug reactions.
5. Interventions whose aim was to increase constructs such as teamwork, safety culture, leadership, etc. were excluded unless they also reported a safety outcome.
6. Simulation studies that used students as study subjects were excluded.
7. Studies to improve care of a disease were in general excluded unless safety was the primary outcome. For example, the numerous studies of interventions to improve care of patients with diabetes, which in general use a measure of glucose control like HgbA1c as their principal outcome, were excluded even if they reported differences in hypoglycemic events.
8. Studies of different agents and different delivery models for anticoagulation were considered to be primarily quality and not safety and were excluded.
9. Many interventions could fall into more than one category. For example, studies of interventions to improve hospital-to-community transitions often used pharmacists and their primary goal was medication safety. We classified each study in only one category. Studies of transitions in care were all classified as transitions. Studies not about transitions where pharmacists were the only or principal intervention component were classified as pharmacist's role. Similarly, studies of e-prescribing usually have medication safety as their goal. We classified studies as e-prescribing if that term was used in the article or if it was described as computerized physician order entry (CPOE) in the outpatient/ambulatory setting. Such studies could include, and often did include, decision support. Studies of decision support for laboratory test monitoring were classified as medication safety.

### Peer Review and Public Commentary

A draft version of the Technical Brief was posted for peer review on November 24, 2015, and revised in response to reviewer comments.