# Peer Reviewers

Prior to publication of the final Technical Brief, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Tara Bishop, M.D., M.P.H.^*^
  Associate Professor of Healthcare Policy and Research Weill Cornell Medicine, Cornell University
  New York, NY
- Lawrence P. Casalino, M.D., M.P.H., Ph.D.
  Livingston Farrand Professor of Public Health Chief, Division of Health Policy and Economics Department of Healthcare Policy and Research Weill Cornell Medicine, New York Presbyterian Hospital
  New York, NY
- Rainu Kaushal, M.D., M.P.H.^*^
  Chair, Healthcare Policy and Research,
  Nanette Laitman Distinguished Professor of Healthcare Policy & Research Principal Investigator, New York City Clinical Data Research Network Executive Director, Health Information Technology Evaluation
  Collaborative Weill Cornell Medicine Chief, Healthcare Policy & Research New York-Presbyterian Hospital
  New York, NY
- Maeve O'Beirne, M.D., Ph.D.
  Associate Professor
  University of Calgary
  Calgary, Alberta, Canada
- Hardeep Singh, M.D., M.P.H.
  Houston Veterans Affairs Health Services Research Center for Innovations, Michael E. DeBakey Veterans Affairs Medical Center and Baylor College of Medicine,
  Houston, TX

* These two individuals completed a joint review