# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the Technical Brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- David Bates, M.D., M.Sc.
  Senior Vice President/Chief Innovation Officer and Chief, Division of General Internal Medicine and Primary Care for Brigham and Women's Hospital
  Boston, MA
- Daniel Budnitz, M.D., M.P.H., CAPT., USPHS.^*^
  Director, Medication Safety Program
  Division of Healthcare Quality Promotion, Centers for Disease Control and Prevention (CDC)
  Atlanta, GA
- Martine Ehrenclou, M.A.^*^
  Patient Advocate
  Los Angeles, CA
- Nancy Elder, M.D.^*^
  Professor, Department of Family and Community Medicine, University of Cincinnati College of Medicine, Medical Director, McMicken Integrated Care Clinic
  Cincinnati, OH
- Tejal K. Gandhi, M.D., M.P.H., C.P.P.S.^*^
  President and Chief Executive Officer of the National Patient Safety Foundation, the NPSF Lucian Leape Institute, and the Certification Board for Professionals in Patient Safety National Patient Safety Foundation
  Boston, MA
- Audrey Lyndon, Ph.D., RNC, FAAN^*^
  Associate Professor and Vice Chair for Academic Personnel, Department of Family Health Care Nursing
  San Francisco, CA
- Gordon Schiff, M.D.^*^
  Associate Director, Center for Patient Safety Research and Practice, Division of General Internal Medicine, Brigham and Women's Hospital
  Associate Professor of Medicine Harvard Medical School, Safety Director Harvard Center for Primary Care Academic Improvement Collaborative
  Boston, MA
- Aziz Sheikh, OBE, B.Sc., M.B.B.S., M.D., M.Sc., FRCGP, FRCP, FRCPE, FFPH, FRSE, F.Med.Sci., FACMI^*^
  Professor of Primary Care Research & Development and Co-Director, Centre of Medical Informatics, Usher Institute of Population Health Sciences and Informatics
  The University of Edinburgh
  Edinburgh Scotland
  Visiting Professor of Medicine,
  Harvard Medical School
  Boston, MA

* This Key Informant (KI) also provided review of the draft report