# Findings

## Overview

The results of the questionnaire survey and KI interviews identified 28 PSPs or targets, not mutually exclusive, that had relevance to the ambulatory care setting. Separate searches on each in PubMed yielded more than 20,000 titles. Titles, abstracts, and full text screening yielded 147 potentially relevant studies, which were mostly concentrated in a few PSPs. The KI interviews were analyzed for themes, which were summarized across two domains. We have included the table of themes in Appendix C.

## Results of the Questionnaire Survey

After receiving input from our project team, an online questionnaire was sent out to our KIs to evaluate which PSPs should or should not be included in our list of practices to focus on. In addition, we asked the KIs to identify additional practices that were not on the list. Completion of the questionnaire by all eight KIs and the project team's input yielded a list of 28 PSPs relevant to ambulatory care settings and 27 excluded practices not relevant to PSPs in ambulatory care settings (see Table 1).

Table 1 Patient safety practices evaluated

PSPs included
Use of Simulation Exercises in Patient Safety Efforts
Obtaining Informed Consent From Patients
Team-Training in Health Care
Computerized Provider Order Entry With Clinical Decision Support Systems
Workforce issues (job satisfaction, environment, etc)
Transitions other than hospital to ambulatory care – care coordination
Self-management of high risk medications (insulin, anticoagulation, immunomodulatory therapy)
Chronic Opioid use
Tracking test results so things don't slip through the cracks (all diagnostic and prevention testing and screening)
Monitoring for medication safety beyond the initial decision to prescribe
Referring risks--Was the best referral made? Was information communicated well enough? Who is responsible for what? (Responsibility and accountability)
Issues of multimorbidity/frail elders beyond polypharmacy
Phone triage—Who staffs it? What support tools are used?
Mental health diagnosis/treatments in the context of integrated health (co-located primary care and mental health) – mental/psychological health across all ambulatory settings
Health Literacy
Infection control and prevention of office-based acquired infections (hand hygiene is on top but there are other issues)
The Joint Commission's “Do Not Use” List
Interventions To Improve Hand Hygiene Compliance
Ensuring Documentation of Patients' Preferences for Life-Sustaining Treatment
Human Factors and Ergonomics
Promoting Engagement by Patients and Families To Reduce Adverse Events/Responsibilities in safety practices
Promoting Culture of Safety
Patient Safety Practices Targeted at Diagnostic Errors
Interventions to Improve Care Transitions at Hospital Discharge
Clinical Pharmacist's Role in Preventing Adverse Drug Events
Medication Reconciliation Supported by Clinical Pharmacists
Monitoring Patient Safety Problems
Preventing Patient Death or Serious Injury Associated With Radiation Exposure From Fluoroscopy and Computed Tomography
PSPs excluded
Identifying Patients at Risk for Suicide
Prevention of Venous Thromboembolism
Issues around Telehealth
Reducing Unnecessary Urinary Catheter Use and Other Strategies To Prevent Catheter-Associated Urinary Tract Infections
Prevention of Central Line-Associated Bloodstream Infections
Interventions To Allow the Reuse of Single-Use Devices
Use of Real-Time Ultrasound Guidance During Central Line Insertion
Interventions To Prevent Contrast-Induced Acute Kidney Injury
Administration of blood products
High-Alert Drugs: Patient Safety Practices for Intravenous Anticoagulants
Barrier Precautions, Patient Isolation, and Routine Surveillance for prevention of Healthcare-Associated Infections
Ventilator-Associated Pneumonia
Preoperative and Anesthesia Checklists
Use of Report Cards and Outcome Measurements To Improve Safety of Surgical Care: American College of Surgeons National Surgical Quality Improvement Program
Prevention of Surgical Items Being Left Inside Patient
Operating Room Integration and Display Systems
Use of Beta Blockers To Prevent Perioperative Cardiac Events
Preventing In-Facility Falls
Preventing In-Facility Delirium
Preventing In-Facility Pressure Ulcers
Inpatient Intensive Glucose Control Strategies To Reduce Death and Infection
Rapid Response Systems
Strategies To Prevent Stress-Related Gastrointestinal Bleeding (Stress Ulcer Prophylaxis)
Effect of Nurse-to-Patient Staffing Ratios on Patient Morbidity and Mortality
Tubing Misconnections
Limiting Individual Provider's Hours of Service (this is in the context of physicians-in-training)
Smart Pumps and Other Protocols for Infusion Pumps

Table Note: PSPs=Patient Safety Practices

This list was reviewed during our KI interviews, and no substantive changes were made. The project team and KIs recognized that many of these included PSPs overlapped, and some published PSPs may fall into more than one category.

## Synthesis of the Key Informant Interviews

The KIs provided wide ranging views on numerous topics related to ambulatory patient safety, which we have organized into the following areas: the need for more fundamental formative work on the implementation of interventions and better measures of safety, specific ambulatory PSPs and concerns (which we refer to as safety issues), and cross-cutting patient safety strategies. We have summarized the interviews in Figure 1 as a matrix encompassing ambulatory care safety (a row for each of six safety issues) and strategies typically considered to address these vulnerabilities (a column for each of six cross-cutting strategies).

Figure 1 Matrix of key informant themes

Figure notes: IT=Information Technology; PCMH=Patient-Centered Medical Homes; gray boxes represents intersections of issues and strategies that KIs did not discuss.

This figure summarizes the interviews into a matrix. The figure is described in more detail in the section entitled “Key Informant Interviews.”

### KI Topic Area 1 Formative Work

KIs emphasized the importance of additional formative work in ambulatory safety in addition to testing and implementation of interventions. This formative work would inform the entire range of safety issues discussed. Several of the KIs recommended that AHRQ convene a consensus process of some kind to prioritize ambulatory safety issues that would lend consistency to local efforts. Several predicted that inquiry into intervention development would increase the uptake and effectiveness of patient safety promotion activities. During KI calls, the importance of interdisciplinary perspectives, including medicine, nursing, human factors, and the social sciences, was mentioned several times. Lack of validated measures remains a pervasive problem. Because ambulatory care is decentralized, KIs recommended use of multiple measures that can be triangulated in order to establish the burden of ambulatory safety problems. One emphasized the importance of developing consensus for measures in order to bring consistency and comparability across studies. The field could also benefit from consistent definitions of safety topics.

### KI Topic Area 2 Safety Issues

The KIs reflected on the wide range of safety practices included. Multiple KIs felt there was a distinction between PSPs that reflected concrete patient safety issues, such as hand hygiene, and PSPs that represented cross-cutting patient safety strategies, such as “promoting a culture of safety.” One KI urged us to consider patient safety strategies separately from specific patient safety issues, because different sets of interventions are needed to address cross-cutting strategies than to address specific patient safety topics. Another recommended considering the strategy and the topic jointly during the intervention design phase. Figure 1 provides some examples of such joint consideration (e.g., decision support as an intervention representing an health IT strategy, and directed at two safety topics).

Across all the discussions, KIs mentioned 5 concrete safety issues relevant to ambulatory settings: medication safety, diagnosis, transitions among providers in ambulatory settings, referrals from one provider to another, and management of test results. There was agreement that each of these issues is complex, multi-faceted, and important for patient safety. They began with general comments about each issue. Briefly, medication safety was defined broadly to include any deviation from optimal medication use, including errors in prescribing, dispensing, and monitoring, as well as failure to note medication interactions or appropriately discontinue medications. Some aspects of medication non-adherence were also seen as safety problems. Multiple KIs gave the same example: a non-adherent patient whose physician adds more antihypertensive agents to his regimen, causing the patient to become over-medicated when he finally does adhere. Delayed or missed diagnosis was felt to be a significant problem needing additional formative and descriptive work on a large scale. Participants noted that ambulatory care is rife with transitions, and recommended looking at transitions broadly, as interactions between all parties involved in patients' health. The referral process also is vulnerable to safety gaps; patients and subspecialty providers often do not know the reason for a visit, and the primary care provider may not receive timely information and feedback. Diagnostic testing exhibits widespread problems in notification and tracking of test results, and patients are variably aware of clinically relevant results.

### KI Topic Area 3 Strategies

KIs also discussed strategies that can be used to improve safety across multiple specific topics. Patient engagement is an example of a safety strategy that could address both diagnostic and medication safety. Six cross-cutting safety strategies emerged from the KI discussions: communication, health information technology (IT), teams, patient and family engagement, organizational approaches, and safety culture. These six areas can be both facilitators of ambulatory safety and, if lacking or sub-optimal, barriers to safety. KIs provided both general input about each area and topic-specific input, which we discuss below.

Communication is clearly critical to ambulatory safety. KIs view current communication processes as vulnerable to safety problems. One specific vulnerability was the lack of implementation of clear medication instructions, despite the availability of evidence-based medication instructions that enhance comprehension. Similarly, the lack of group communication among multiple providers was viewed as a barrier to timely and accurate diagnosis. Experts reported an unmet need for synchronous communication at times of transition in ambulatory settings. One KI suggested that the communication practices embedded in the Patient-Centered Medical Home (PCMH) have the potential to enhance patient safety.

Health IT was cited as both a strategy to improve safety and a barrier to safety. KIs considered poor usability of current electronic health records (EHRs) to be a safety vulnerability and a source of clinician burnout. Burnout includes symptoms and signs such as emotional exhaustion, cynicism, perceived clinical ineffectiveness, and a sense of depersonalization in relationships with colleagues and/or patients.^12^ They cited the increasing reports of alert fatigue, in which the proliferation of meaningless alerts leads to clinicians ignoring automated alerts. There was also concern about the quality of communication in visits when the physician or provider is focused on the electronic health record. However, there was agreement among KIs that health IT has potential to improve safety in ambulatory settings broadly and for specific safety issues like transitions in care and diagnosis. They saw potential in using decision support to enhance diagnosis, and believed that interaoperable health IT platforms could eventually address medication reconciliation. Technology also has the potential to engage patients, especially between visits.

How work roles within teams are constructed, workflow managed, and teamwork monitored all can influence patient safety. For ambulatory care, the KIs envisioned increasing the role of nurse practitioners, physician assistants, and other health care team members in order to foster safety. Including pharmacists on ambulatory teams was specifically mentioned, as was employing a team approach to transitions.

KIs consistently highlighted the importance of patient engagement since ambulatory encounters are rare and brief compared with daily self-management. KIs discussed the need for evidence to inform optimal patient engagement strategies. KIs believed is critical that patient engagement strategies address the needs of populations with limited health literacy, limited English proficiency, and other social vulnerabilities. Making the health system easier for patients to navigate was felt to confer safety benefit.

KIs expressed concern about the notable lack of existing organizational approaches in current practice that support ambulatory safety. They also expressed concern about “complacency” about errors in ambulatory practice and believed that strengthening reporting and feedback mechanisms would help. KIs felt that the patient-centered medical home (PCMH) approach had promise, and recommended further study of how PCMH transformation affects adverse event incidence.

Measurement remains a challenge for ambulatory safety. Currently, we do not have effective measurement strategies. KIs believed that multiple modes of measurement including EHR-derived measures, patient and clinician reports, and record review, would need to be used in combination to effectively detect and measure the spectrum of ambulatory safety gaps.

Finally, an overarching theme that emerged from the discussions was the current rapid transformation of the ambulatory environment, and the need to take this rapidly changing context into account when examining safety hazards and interventions to improve ambulatory safety. Much of the current literature is derived from traditional ambulatory care models, and these are likely to be replaced by new models in the future. Thus, there is an urgent need for rapid-cycle evaluation of the impact of new care delivery models on safety.

## Results of the Literature Scan

Figure 2 presents the results of the screening of the titles, abstracts, and full text articles. The searches of PubMed on the 28 topics yielded a total of 21,927 titles with an additional 61 titles coming from grey literature. Some titles appeared in more than one search, and as we did not de-duplicate these 28 searches the total number of unique titles is somewhat less. From these titles, one reviewer screened the titles, abstract, and full text articles. The majority of studies excluded at abstract screening were because they were not hypothesis-testing studies of patient safety interventions, or not about patient safety, or not based in ambulatory care (see Figure 2).

Figure 2 Overview of screening

Figure notes: PSP(s)=Patient Safety Practice(s)

Figure 2 is the flow chart that summarizes the study retrieval and selection process for articles. The information displayed in the figure is described in the section entitled Results of Literature Searches.

Of the 3,039 abstracts selected at full text screening, 361 articles were retrieved and reviewed. Two hundred and fourteen articles were rejected on further review, most because they were not hypothesis-testing studies of PSPs. One hundred and forty-seven studies met our eligibility criteria.

We also identified a number of authoritative reports and commentaries, such as the CDC Infection Prevention Resources for outpatient settings and the AMA report on Ambulatory Patient Safety.^13,9^ However, these reports and commentaries were rejected because our literature scan was restricted to hypothesis-testing studies.

Of the studies meeting eligibility criteria, the PSPs that were the subject of the greatest number of studies were e-prescribing, medication safety, pharmacist-led interventions, and transitions of care (see Table 2). These PSPs also all already have systematic reviews of their effectiveness (60 percent published within the past two years), although not all the reviews are exclusively focused on ambulatory care-based versions of these interventions. However, even within the PSP that had the most identified studies, medication safety, the published studies have a relatively narrow focus and setting. Table 3 shows the intervention and setting for the 28 medication safety studies that were not systematic reviews. These are dominated by studies of computerized decision support and/or alerts as part of CPOE or the electronic health record and implemented in academic health care settings or large managed care organizations.

Table 2 Included studies by topic

Included studies, N=147

| Study Design
Safety Practice | Systematic Review | RCT | Other hypothesis testing study | Practice guideline | TOTAL
Diagnostic errors | | | | | 0
E-prescribing | 6 | 2 | 22 | | 30
Hand hygiene | | | 2 | | 2
Health literacy | | | 1 | | 1
Human factors | | 1 | | | 1
Infection control | | | 2 | 1 | 3
Informed consent | | | 1 | | 1
JCAHO “Do Not Use” list | | | | | 0
Life-sustaining treatment | | | | | 0
Medication safety | 5 | 12 | 16 | | 33
Mental health | | | | | 0
Monitoring | | | 1 | | 1
Multimorbidity | | | | | 0
Opioid use | | | 3 | | 3
Patient engagement | | 4 | 2 | | 6
Pharmacists' role | 2 | 1 | 14 | | 17
Radiation exposure | | | 1 | | 1
Referrals | | | | | 0
Safety culture | | 1 | | | 1
Self-management | | | | | 0
Simulation | | | 7 | | 7
Team-training | | | 1 | | 1
Telephone triage | 3 | | 3 | | 6
Tracking test results | | 1 | 2 | | 3
Transitions | 7 | 10 | 13 | | 30
Workforce | | | | | 0
TOTALS: | 23 | 32 | 91 | 1 | 147

notes: PSP(s)=Patient Safety Practice(s)

Table 3 Settings for medication safety

Author, Year | Intervention | Setting
Armstrong, 2014^14^ | Fax alert Computer-assisted | Providers in two large health plans
Bhardwaja, 2011^15^ | Computer alert | Pharmacists in a large managed care organization
Boyle, 2013^16^ | “Standardized CQI” that includes computerized decision support | Community pharmacists
Bundy, 2012^17^ | EHR assisted paper drug bulletins | Two federally qualified health centers
Collins, 2011^18^ | CPOE with decision support | Ambulatory cancer center
Gabe, 2014^19^ | Standardized symptom questionnaire | Ambulatory respiratory care clinic
Glassman, 2007^20^ | Provider feedback added to EHR with CPOE and decision support | Veterans Affairs ambulatory care clinic
Griesbach, 2015^21^ | EHR Drug Alerts | 780 physicians in an Accountable Care Organization
Harrison, 2015^22^ | Computing-assisted warfarin dosing | 15 community pharmacists
Hsu, 2014^23^ | CPOE alert | Academic medical center with 2.5 million ambulatory visits per year
Kansagra, 2011^24^ | Registry of chemotherapy toxicity admission | Ambulatory cancer facility
Lau, 2013^25^ | EHR with decision support | 400 physician medical group
Lukasweski, 2012^26^ | Web-based tool for patients to identify potential medication safety concerns | 29 members of a community-based organization devoted to healthy aging
Lopez-Picazo, 2011^27^ | EHR with decision support | All primary care physicians in a region of Spain
Matheny, 2008^28^ | EHR with decision support | Primary care physicians at 20 clinics
Palen, 2006^29^ | EHR with decision support | 16 ambulatory sites in a managed care organization
Raebel, 2005^30^ | Computerized alerts | A large managed care organization
Raebel, 2006^31^ | Computerized alerts | A large managed care organization
Raebel, 2007^32^ | Computerized alerts | A large managed care organization
Raebel, 2007^33^ | Computerized alerts | A large managed care organization
Ryan, 2013^34^ | Two methods for medication reconciliation | Ambulatory clinic at an academic medical center
Singh, 2012^35^ | Web-based QI program | Eight primary care practices
Smith, 2006^36^ | CPOE with decision support | One health maintenance organization
Stock, 2008^37^ | EHR and web-based methods for medication reconciliation | A large health plan
Tanner, 2015^38^ | EHR | 209 primary care practices
Touchette, 2012^39^ | Medication therapy management programs | Three geographically disparate academic health care systems
Wessell, 2013^40^ | A multi-method quality improvement intervention | 20 primary care practices
Willis, 2011^41^ | In house medication reconciliation by trained health care students | 111 patients aged 65 or older who consented to a home visit

notes: CPOE=Computerized physician order entry; CQI=Continuous Quality Improvement; EHR=Electronic Health Record

Studies meeting eligibility criteria for the other PSPs or safety targets were few. Those PSPs that have systematic reviews have been implemented in more than one setting, although frequently the exact nature of the PSP differs from study to study (for example, studies of pharmacist-led interventions vary in exactly what the pharmacist does and when). PSPs for which published studies are few have, in general, only been assessed in a single setting. The list of included studies by topic can be found in Appendix D.

We did not identify any studies, focusing on Guiding Question #2, concerning organizational models that promote the uptake and spread of ambulatory PSPs.