# Background

## Introduction

The Institute of Medicine defines patient safety as “freedom from accidental injury” when patients receive health care. The goal of the patient safety movement is to prevent adverse events in health care. We employ the standard definition of adverse events, as previously adapted for ambulatory care: harm to patients arising from medical management, or patient self-management, rather than the natural history of disease.^1-4^

Even though most of medical care occurs in ambulatory settings, the patient safety movement originated in, and has been mainly focused on, adverse events among hospitalized patients. However, it is increasingly clear that the ambulatory setting is critically important; the National Academy of Medicine (Institute of Medicine) opined that adverse events may be more common in ambulatory settings than in acute care settings.^5^ Like hospital care, ambulatory patient safety practices (PSPs) are probably somewhat or very sensitive to context, including size and complexity of the practice, financing, culture, and leadership.

Ambulatory care differs substantially from inpatient care in ways that affect patient safety interventions. First, ambulatory settings have traditionally lacked electronic health records and other technological tools that can be harnessed for safety. Paper records constitute an impediment to timely safety data management and reporting. Today, the HITECH (Health Information Technology for Economic and Clinical Health) Act, through which $30 billion of federal incentive payments were distributed to physicians and hospitals to promote digital adoption, has led to a marked increase in adoption of health Information Technology (IT)^6^ in ambulatory settings. This makes it more feasible to employ technology-based safety interventions. However, ambulatory care remains fragmented, with the vast majority of care delivered in small practices that use different, and non interoperable, electronic platforms.

Next, the traditional visit-based model of ambulatory care, in which patients periodically have short visits with ambulatory providers, creates potential safety gaps. The time course of ambulatory care is longer; weeks or months can elapse between visits or referrals or diagnostic studies, creating additional challenges for patient safety. Ambulatory providers experience intense time pressure, with current incentives focused on seeing as many patients as possible in a given amount of time, and in small practices, lack support staff for coordination of care.^7^ The presence and composition of team- including nurses, pharmacists, assistants, and others- in office settings varies greatly and can affect patient safety as well.

Most of the time, patients, especially those with chronic conditions, are actually self-managing.^8^ The role of the patient is very different in ambulatory care settings than in the hospital.^9^ In acute-care settings, patients are under close observation and often passively receive care. In ambulatory settings, patients must decide when to initiate medical care, interact with ambulatory health systems, follow provider recommendation and perform their daily health-related tasks. For those with multiple chronic diseases, this includes following a disease-specific medication, diet, and exercise regimen. Some also adjust their medication based on their measurements, such as using glucose monitoring to adjust insulin dosing. When patients have difficulty with these self-management activities, they are at risk for adverse events.

Moreover, human error in the hospital typically refers to errors committed by members of the health care team in a professional setting. When we consider error in ambulatory settings, we must include the possibility of patient errors. The distinction between patient error and patient blame is critical. Errors in self-management can occur because providers or health systems do not provide patients or caregivers with the knowledge or skills that patients need to safely self-manage their health conditions. Patients themselves acknowledge that they can err in self-administering medications or interpreting symptoms.^10^ Thus, patient safety issues encompass both the systems issues commonly studied in inpatient settings as well as broader, patient-centered concerns related to communication and shared decision-making.

## Objective of This Technical Brief

In Fiscal Year 2015, the Agency for Healthcare Research and Quality (AHRQ) launched a multi-year initiative to expand the scientific evidence, strategies, and tools that are available for improving patient safety in all health care settings so that people can expect safe care whenever and wherever they receive it. AHRQ has focused on two health care settings—ambulatory care and long-term care facilities.

To better understand the scope of ambulatory care safety issues and the types of interventions that have been reported for ambulatory PSP, we were tasked by AHRQ to provide an overview of key issues relating to improve patient safety. We combined information we obtained from published literature, grey literature, and Key Informant (KI) discussions in order to examine what hospital-based PSPs are applicable to ambulatory care, what additional ambulatory care PSPs exist, what evaluations have been done of patient PSPs in the ambulatory care setting, what is the amount of, and quality of, the evaluations of PSPs in ambulatory care, and what is the evidence about spread and adoption of these practices. We also identified gaps in the current evidence base. Performing a systematic review of the effectiveness of ambulatory PSP interventions is not an objective of this Technical Brief.

## Guiding Questions

The questions below guided the data collection for this Technical Brief. These guiding questions were developed by AHRQ prior to the start of the Technical Brief. Question 1 seeks to identify ambulatory care patient safety practices that have been studied and how widely they have been implemented. Question 2 seeks information on organizational settings and other factors that may influence uptake and effectiveness ambulatory care patient safety practices.

Guiding Question 1. What are the evidence-based hospital patient safety practices that may be applicable to the ambulatory care setting? What are the ambulatory care patient safety practices that have been studied in the literature? Which ones have not been broadly implemented or studied beyond a single ambulatory care center?

Guiding Question 2. What tools, settings, and other factors (such as implementation of Patient-Centered Medical Home and team-based care) may influence the implementation and spread of ambulatory care patient safety practices?