# Appendix D List of Included Studies by Topic

## E-Prescribing

1 Abramson EL, Barron Y, Quaresimo J, et al. (2011). Electronic prescribing within an electronic health record reduces ambulatory prescribing errors. Jt Comm J Qual Patient Saf.
2 Abramson EL, Malhotra S, Fischer K, et al. (2011). Transitioning between electronic health records: effects on ambulatory prescribing safety. J Gen Intern Med.
3 Abramson EL, Malhotra S, Osorio SN, et al. (2013). A long-term follow-up evaluation of electronic health record prescribing safety. J Am Med Inform Assoc.
4 Abramson EL, Pfoh ER, Barron Y, et al. (2013). The effects of electronic prescribing by community-based providers on ambulatory medication safety. Jt Comm J Qual Patient Saf.
5 Ammenwerth E, Schnell-Inderst P, Machan C, et al. (2008). The effect of electronic prescribing on medication errors and adverse drug events: a systematic review. J Am Med Inform Assoc.
6 Black AD, Car J, Pagliari C, et al. (2011). The impact of eHealth on the quality and safety of health care: a systematic overview. PLoS Med.
7 Carling CL, Kirkehei I, Dalsbo TK, et al. (2013). Risks to patient safety associated with implementation of electronic applications for medication management in ambulatory care--a systematic review. BMC Med Inform Decis Mak.
8 Coleman JJ, Hemming K, Nightingale PG, et al. (2011). Can an electronic prescribing system detect doctors who are more likely to make a serious prescribing error?. J R Soc Med.
9 Crosson JC, Etz RS, Wu S, et al. (2011). Meaningful use of electronic prescribing in 5 exemplar primary care practices. Ann Fam Med.
10 Dainty KN, Adhikari NK, Kiss A, et al. (2012). Electronic prescribing in an ambulatory care setting: a cluster randomized trial. J Eval Clin Pract.
11 Devine EB, Hansen RN, Wilson-Norton JL, et al. (2010). The impact of computerized provider order entry on medication errors in a multispecialty group practice. J Am Med Inform Assoc.
12 Devine EB, Wilson-Norton JL, Lawless NM, et al. (2008). Advances in Patient Safety Implementing an Ambulatory e-Prescribing System: Strategies Employed and Lessons Learned to Minimize Unintended Consequences. Henriksen K, Battles JB, Keyes MA, Grady ML, editors. Advances in Patient Safety: New Directions and Alternative Approaches.
13 Dhavle AA, Corley ST, Rupp MT, et al. (2014). Evaluation of a user guidance reminder to improve the quality of electronic prescription messages. Appl Clin Inform.
14 Esmaeil Zadeh P, Tremblay MC. (2015). A review of the literature and proposed classification on e-prescribing: Functions, assimilation stages, benefits, concerns, and risks. Res Social Adm Pharm.
15 Fernandopulle R, Patel N. (2010). How the electronic health record did not measure up to the demands of our medical home practice. Health Aff (Millwood).
16 Hayward J, Thomson F, Milne H, et al. (2013). ‘Too much, too late’: mixed methods multi-channel video recording study of computerized decision support systems and GP prescribing. J Am Med Inform Assoc.
17 Isaac T, Weissman JS, Davis RB, et al. (2009). Overrides of medication alerts in ambulatory care. Arch Intern Med.
18 Kaushal R, Barron Y, Abramson EL. (2011). The comparative effectiveness of 2 electronic prescribing systems. Am J Manag Care.
19 Kaushal R, Kern LM, Barron Y, et al. (2010). Electronic prescribing improves medication safety in community-based office practices. J Gen Intern Med.
20 Kukreti V, Cosby R, Cheung A, et al. (2014). Computerized prescriber order entry in the outpatient oncology setting: from evidence to meaningful use. Curr Oncol.
21 Moniz TT, Seger AC, Keohane CA, et al. (2011). Addition of electronic prescription transmission to computerized prescriber order entry: Effect on dispensing errors in community pharmacies. Am J Health Syst Pharm.
22 Overhage JM, Gandhi TK, Hope C, et al. (2015). Ambulatory Computerized Prescribing and Preventable Adverse Drug Events. J Patient Saf.
23 Palchuk MB, Fang EA, Cygielnik JM, et al. (2010). An unintended consequence of electronic prescriptions: prevalence and impact of internal discrepancies. J Am Med Inform Assoc.
24 Phillips JL, Shea JM. (2015). Impact of Early Electronic Prescribing on Pharmacists' Clarification Calls in Four Community Pharmacies Located in St John's, Newfoundland.
25 Porterfield A, Engelbert K, Coustasse A. (2014). Electronic prescribing: improving the efficiency and accuracy of prescribing in the ambulatory care setting. Perspect Health Inf Manag.
26 Powers C, Gabriel MH, Encinosa W, et al. (2015). Meaningful Use stage 2 e-prescribing threshold and adverse drug events in the Medicare Part D population with diabetes. J Am Med Inform Assoc.
27 Russ AL, Chen S, Melton BL, et al. (2015). Design and Evaluation of an Electronic Override Mechanism for Medication Alerts to Facilitate Communication Between Prescribers and Pharmacists. Ann Pharmacother.
28 Tamblyn R, Huang A, Taylor L, et al. (2008). A randomized trial of the effectiveness of on-demand versus computer-triggered drug decision support in primary care. J Am Med Inform Assoc.
29 Turchin A, Shubina M, Goldberg S. (2011). Unexpected effects of unintended consequences: EMR prescription discrepancies and hemorrhage in patients on warfarin. AMIA Annu Symp Proc.
30 Yu DT, Seger DL, Lasser KE, et al. (2011). Impact of implementing alerts about medication black-box warnings in electronic health records. Pharmacoepidemiol Drug Saf.

## Hand hygiene

1 Bittle MJ, LaMarche S. (2009). Engaging the patient as observer to promote hand hygiene compliance in ambulatory care. Jt Comm J Qual Patient Saf.
2 Stackelroth J, Sinnott M, Shaban RZ. (2015). Hesitation and error: Does product placement in an emergency department influence hand hygiene performance?. Am J Infect Control.

## Health literacy

1 Wolf MS, Davis TC, Bass PF, et al. (2010). Improving prescription drug warnings to promote patient comprehension. Arch Intern Med.

## Human factors

1 Melton BL, Zillich AJ, Russell SA, et al. (2015). Reducing prescribing errors through creatinine clearance alert redesign. Am J Med.

## Infection control

1 (2007). Infection prevention and control in pediatric ambulatory settings. Pediatrics.
2 Podczervinski S, Stednick Z, Helbert L, et al. (2015). Employee influenza vaccination in a large cancer center with high baseline compliance rates: comparison of carrot versus stick approaches. Am J Infect Control.
3 Savant AP, O'Malley C, Bichl S, et al. (2014). Improved patient safety through reduced airway infection rates in a paediatric cystic fibrosis programme after a quality improvement effort to enhance infection prevention and control measures. BMJ Qual Saf.

## Informed consent

1 Lutjeboer J, Burgmans MC, Chung K, et al. (2015). Impact on Patient Safety and Satisfaction of Implementation of an Outpatient Clinic in Interventional Radiology (IPSIPOLI-Study): A Quasi-Experimental Prospective Study. Cardiovasc Intervent Radiol.

## Medication safety

1 Armstrong EP, Wang SM, Hines LE, et al. (2014). Prescriber perceptions of a near real-time fax alert program for potential drug-drug interactions. J Manag Care Spec Pharm.
2 Bhardwaja B, Carroll NM, Raebel MA, et al. (2011). Improving prescribing safety in patients with renal insufficiency in the ambulatory setting: the Drug Renal Alert Pharmacy (DRAP) program. Pharmacotherapy.
3 Boyle TA, Ho C, Mackinnon NJ, et al. (2013). Safety implications of standardized continuous quality improvement programs in community pharmacy. J Pharm Pract.
4 Bundy DG, Marsteller JA, Wu AW, et al. (2012). Electronic health record-based monitoring of primary care patients at risk of medication-related toxicity. Jt Comm J Qual Patient Saf.
5 Collins CM, Elsaid KA. (2011). Using an enhanced oral chemotherapy computerized provider order entry system to reduce prescribing errors and improve safety. Int J Qual Health Care.
6 Fischer SH, Tjia J, Field TS. (2010). Impact of health information technology interventions to improve medication laboratory monitoring for ambulatory patients: a systematic review. J Am Med Inform Assoc.
7 Gabe ME, Murphy F, Davies GA, et al. (2014). Medication monitoring in a nurse-led respiratory outpatient clinic: pragmatic randomised trial of the West Wales Adverse Drug Reaction Profile. PLoS One.
8 Garcia-Caballos M, Ramos-Diaz F, Jimenez-Moleon JJ, et al. (2010). Drug-related problems in older people after hospital discharge and interventions to reduce them. Age Ageing.
9 Glassman PA, Belperio P, Lanto A, et al. (2007). The utility of adding retrospective medication profiling to computerized provider order entry in an ambulatory care population. J Am Med Inform Assoc.
10 Griesbach S, Lustig A, Malsin L, et al. (2015). Best practices: an electronic drug alert program to improve safety in an accountable care environment. J Manag Care Spec Pharm.
11 Harrison J, Shaw JP, Harrison JE. (2015). Anticoagulation management by community pharmacists in New Zealand: an evaluation of a collaborative model in primary care. Int J Pharm Pract.
12 Hayward GL, Parnes AJ, Simon SR. (2009). Using health information technology to improve drug monitoring: a systematic review. Pharmacoepidemiol Drug Saf.
13 Hsu CC, Chou CY, Chou CL, et al. (2014). Impact of a warning CPOE system on the inappropriate pill splitting of prescribed medications in outpatients. PLoS One.
14 Kansagra A, Linden E. (2011). Systematic Tracking and Analysis of Admissions for Chemotherapy Toxicity Inform Quality Improvement Efforts, Leading to Reduced Toxicity Risk. Service Delivery Innovation Profile.
15 Lainer M, Mann E, Sonnichsen A. (2013). Information technology interventions to improve medication safety in primary care: a systematic review. Int J Qual Health Care.
16 Lau B, Overby CL, Wirtz HS, et al. (2013). The association between use of a clinical decision support tool and adherence to monitoring for medication-laboratory guidelines in the ambulatory setting. Appl Clin Inform.
17 Lopez-Picazo JJ, Ruiz JC, Sanchez JF, et al. (2011). A randomized trial of the effectiveness and efficiency of interventions to reduce potential drug interactions in primary care. Am J Med Qual.
18 Lukazewski A, Mikula B, Servi A, et al. (2012). Evaluation of a web-based tool in screening for medication-related problems in community-dwelling older adults. Consult Pharm.
19 Matheny ME, Sequist TD, Seger AC, et al. (2008). A randomized trial of electronic clinical reminders to improve medication laboratory monitoring. J Am Med Inform Assoc.
20 Palen TE, Raebel M, Lyons E, et al. (2006). Evaluation of laboratory monitoring alerts within a computerized physician order entry system for medication orders. Am J Manag Care.
21 Raebel MA, Carroll NM, Kelleher JA, et al. (2007). Randomized trial to improve prescribing safety during pregnancy. J Am Med Inform Assoc.
22 Raebel MA, Charles J, Dugan J, et al. (2007). Randomized trial to improve prescribing safety in ambulatory elderly patients. J Am Geriatr Soc.
23 Raebel MA, Chester EA, Newsom EE, et al. (2006). Randomized trial to improve laboratory safety monitoring of ongoing drug therapy in ambulatory patients. Pharmacotherapy.
24 Raebel MA, Lyons EE, Chester EA, et al. (2005). Improving laboratory monitoring at initiation of drug therapy in ambulatory care: a randomized trial. Arch Intern Med.
25 Ryan GJ, Caudle JM, Rhee MK, et al. (2013). Medication reconciliation: comparing a customized medication history form to a standard medication form in a specialty clinic (CAMPII 2). J Patient Saf.
26 Singh R, Anderson D, McLean-Plunkett E, et al. (2012). IT-enabled systems engineering approach to monitoring and reducing ADEs. Am J Manag Care.
27 Smith DH, Perrin N, Feldstein A, et al. (2006). The impact of prescribing safety alerts for elderly persons in an electronic medical record: an interrupted time series evaluation. Arch Intern Med.
28 Stock R. (2008). Reconciliation of Patient and Provider Medication Lists Reduces Discrepancies and Enhances Medication Safety in Physician Clinics. Archived Service Delivery Innovation Profile.
29 Tanner C, Gans D, White J, et al. (2015). Electronic health records and patient safety: co-occurrence of early EHR implementation with patient safety practices in primary care settings. Appl Clin Inform.
30 Touchette DR, Masica AL, Dolor RJ, et al. (2012). Safety-focused medication therapy management: a randomized controlled trial. J Am Pharm Assoc (2003).
31 Viswanathan M, Kahwati LC, Golin CE, et al. (2014). AHRQ Comparative Effectiveness Reviews. Medication Therapy Management Interventions in Outpatient Settings.
32 Wessell AM, Ornstein SM, Jenkins RG, et al. (2013). Medication Safety in Primary Care Practice: results from a PPRNet quality improvement intervention. Am J Med Qual.
33 Willis JS, Hoy RH, Jenkins WD. (2011). In-home medication reviews: a novel approach to improving patient care through coordination of care. J Community Health.

## Monitoring

1 Danforth KN, Smith AE, Loo RK, et al. (2014). Electronic Clinical Surveillance to Improve Outpatient Care: Diverse Applications within an Integrated Delivery System. EGEMS (Wash DC).

## Opioid use

1 Kattan J. (2014). Cross-Agency Mayoral Task Force Promotes Policies and Initiatives To Reduce Prescription Opioid Misuse and Related Problems, Achieves Some Early Successes. Policy Innovation Profile.
2 Von Korff M. (2013). Multifaceted Program Featuring Guideline, Training, and Incentives Reduces Prescribing of High-Dose Opioid Therapy in Patients With Chronic Pain. Service Delivery Innovation Profile.
3 Westanmo A, Marshall P, Jones E, et al. (2015). Opioid Dose Reduction in a VA Health Care System--Implementation of a Primary Care Population-Level Initiative. Pain Med.

## Patient engagement

1 Evans CT, Hill JN, Guihan M, et al. (2014). Implementing a patient education intervention about Methicillin-resistant Staphylococcus aureus prevention and effect on knowledge and behavior in veterans with spinal cord injuries and disorders: a pilot randomized controlled trial. J Spinal Cord Med.
2 Heyworth L, Paquin AM, Clark J, et al. (2014). Engaging patients in medication reconciliation via a patient portal following hospital discharge. J Am Med Inform Assoc.
3 Lesselroth B, Felder R, Adams S. (2010). VA Patients Use Waiting Room Kiosk to Enter Medication List, Facilitating Reconciliation With Electronic Medical Record and Identifying More Discrepancies. Service Delivery Innovation Profile.
4 Tannenbaum C, Martin P, Tamblyn R, et al. (2014). Reduction of inappropriate benzodiazepine prescriptions among older adults through direct patient education: the EMPOWER cluster randomized trial. JAMA Intern Med.
5 Weingart SN, Carbo A, Tess A, et al. (2013). Using a patient internet portal to prevent adverse drug events: a randomized, controlled trial. J Patient Saf.
6 Wilde MH, McMahon JM, McDonald MV, et al. (2015). Self-management intervention for long-term indwelling urinary catheter users: randomized clinical trial. Nurs Res.

## Pharmacists' role

1 Avery AJ, Rodgers S, Cantrill JA, et al. (2012). A pharmacist-led information technology intervention for medication errors (PINCER): a multicentre, cluster randomised, controlled trial and cost-effectiveness analysis. Lancet.
2 Cardwell TB, Bean R. (2011). Pharmacist Provides Telephone-Based Medication Reconciliation and Education to Recently Discharged Patients, Leading to Fewer Readmissions. Service Delivery Innovation Profile.
3 Green MR. (2008). Clinical Pharmacists Provide Outpatient Medication Management to Patients With Severe Diabetes and Those on Anticoagulants, Leading to Improved Outcomes and Lower Costs. Service Delivery Innovation Profile.
4 Haas-Gehres A, Sebastian S, Lamberjack K. (2014). Impact of pharmacist integration in a pediatric primary care clinic on vaccination errors: a retrospective review. J Am Pharm Assoc (2003).
5 Hanson RL, Gannon MJ, Khamo N, et al. (2013). Improvement in safety monitoring of biologic response modifiers after the implementation of clinical care guidelines by a specialty. J Manag Care Pharm.
6 Kurtis J. (2013). Hospital–Retail Pharmacy Partnership Provides Inhospital and Postdischarge Support to At-Risk Patients, Leading to Fewer Readmissions and High Patient Satisfaction. Service Delivery Innovation Profile.
7 Lovely JK, Larson DW, Quast JM. (2014). A clinical practice agreement between pharmacists and surgeons streamlines medication management. Jt Comm J Qual Patient Saf.
8 Lee JK, Slack MK, Martin J, et al. (2013). Geriatric patient care by U.S. pharmacists in healthcare teams: systematic review and meta-analyses. J Am Geriatr Soc.
9 Lindahl K. (2008). Pharmacist-Led Grocery, Store–Based Medication Review Reduces Falls and Enhances Compliance for Medicare Managed Care Members. Service Delivery Innovation Profile.
10 Robbins CM, Stillwell T, Johnson D, et al. (2013). Integrating patient safety and clinical pharmacy services into the care of a high-risk, ambulatory population: a collaborative approach. J Patient Saf.
11 Robinson M, Gunning K, Pippitt K, et al. (2013). Team-based approach to addressing simvastatin safety concerns. J Am Pharm Assoc (2003).
12 Schneider PJ. (2013). Evaluating the impact of telepharmacy. Am J Health Syst Pharm.
13 Teichert M, Griens F, Buijs E, et al. (2014). Effectiveness of interventions by community pharmacists to reduce risk of gastrointestinal side effects in nonselective nonsteroidal anti-inflammatory drug users. Pharmacoepidemiol Drug Saf.
14 Teichert M, Luijben SN, Wereldsma A, et al. (2013). Implementation of medication reviews in community pharmacies and their effect on potentially inappropriate drug use in elderly patients. Int J Clin Pharm.
15 Thomas R, Huntley AL, Mann M, et al. (2014). Pharmacist-led interventions to reduce unplanned admissions for older people: a systematic review and meta-analysis of randomised controlled trials. Age Ageing.
16 Warholak TL, Rupp MT, Leal S, et al. (2014). Assessing the effect of providing a pharmacist with patient diagnosis on electronic prescription orders: a pilot study. Res Social Adm Pharm.
17 Watson LC, Esserman DA, Ivey JL, et al. (2014). Enhancing Quality in Psychiatry with Psychiatrists (EQUIPP)--results from a pilot study. Am J Geriatr Psychiatry.

## Radiation exposure

1 Sodhi KS, Krishna S, Saxena AK, et al. (2015). Clinical application of ‘Justification’ and ‘Optimization’ principle of ALARA in pediatric CT imaging: “How many children can be protected from unnecessary radiation?”. Eur J Radiol.

## Safety culture

1 Hoffmann B, Muller V, Rochon J, et al. (2014). Effects of a team-based assessment and intervention on patient safety culture in general practice: an open randomised controlled trial. BMJ Qual Saf.

## Simulation

1 Brooks-Buza H, Fernandez R, Stenger JP. (2011). The use of in situ simulation to evaluate teamwork and system organization during a pediatric dental clinic emergency. Simul Healthc.
2 Crofts JF, Fox R, Ellis D, et al. (2008). Observations from 450 shoulder dystocia simulations: lessons for skills training. Obstet Gynecol.
3 Duncan DR, Morgenthaler TI, Ryu JH, et al. (2009). Reducing iatrogenic risk in thoracentesis: establishing best practice via experiential training in a zero-risk environment. Chest.
4 LaVelle BA, McLaughlin JJ. (2008). Advances in Patient Safety Simulation-Based Education Improves Patient Safety in Ambulatory Care. Henriksen K, Battles JB, Keyes MA, Grady ML, editors. Advances in Patient Safety: New Directions and Alternative Approaches (Vol. 3: Performance and Tools).
5 Prakash V, Koczmara C, Savage P, et al. (2014). Mitigating errors caused by interruptions during medication verification and administration: interventions in a simulated ambulatory chemotherapy setting. BMJ Qual Saf.
6 Unsworth J, Tuffnell C, Platt A. (2011). Safer care at home: use of simulation training to improve standards. Br J Community Nurs.
7 White RE, Trbovich PL, Easty AC, et al. (2010). Checking it twice: an evaluation of checklists for detecting medication errors at the bedside using a chemotherapy model. Qual Saf Health Care.

## Team training

1 Bunnell CA, Gross AH, Weingart SN, et al. (2013). High performance teamwork training and systems redesign in outpatient oncology. BMJ Qual Saf.

## Telephone triage

1 Bunn F, Byrne G, Kendall S. (2005). The effects of telephone consultation and triage on healthcare use and patient satisfaction: a systematic review. Br J Gen Pract.
2 Derkx HP, Rethans JJ, Muijtjens AM, et al. (2008). Quality of clinical aspects of call handling at Dutch out of hours centres: cross sectional national study. BMJ.
3 Giesen P, Ferwerda R, Tijssen R, et al. (2007). Safety of telephone triage in general practitioner cooperatives: do triage nurses correctly estimate urgency?. Qual Saf Health Care.
4 Huibers L, Smits M, Renaud V, et al. (2011). Safety of telephone triage in out-of-hours care: a systematic review. Scand J Prim Health Care.
5 Ismail SA, Gibbons DC, Gnani S. (2013). Reducing inappropriate accident and emergency department attendances: a systematic review of primary care service interventions. Br J Gen Pract.
6 Meer A, Gwerder T, Duembgen L, et al. (2012). Is computer-assisted telephone triage safe? A prospective surveillance study in walk-in patients with non-life-threatening medical conditions. Emerg Med J.

## Tracking test results

1 Dalal AK, Roy CL, Poon EG, et al. (2014). Impact of an automated email notification system for results of tests pending at discharge: a cluster-randomized controlled trial. J Am Med Inform Assoc.
2 Grossman E, Phillips RS, Weingart SN. (2010). Performance of a fail-safe system to follow up abnormal mammograms in primary care. J Patient Saf.
3 Singh H, Thomas EJ, Mani S, et al. (2009). Timely follow-up of abnormal diagnostic imaging test results in an outpatient setting: are electronic medical records achieving their potential?. Arch Intern Med.

## Transitions

1 Allen J, Hutchinson AM, Brown R, et al. (2014). Quality care outcomes following transitional care interventions for older people from hospital to home: a systematic review. BMC Health Serv Res.
2 Altfeld SJ, Shier GE, Rooney M, et al. (2013). Effects of an enhanced discharge planning intervention for hospitalized older adults: a randomized trial. Gerontologist.
3 Boerner N, Keen JA. (2011). Transitional Care Program With Advance Care Planning for Frail Elders Reduces Emergency Department Visits and Readmissions. Service Delivery Innovation Profile.
4 Bonnet-Zamponi D, d'Arailh L, Konrat C, et al. (2013). Drug-related readmissions to medical units of older adults discharged from acute geriatric units: results of the Optimization of Medication in AGEd multicenter randomized controlled trial. J Am Geriatr Soc.
5 Cavanaugh JJ, Lindsey KN, Shilliday BB, et al. (2015). Pharmacist-coordinated multidisciplinary hospital follow-up visits improve patient outcomes. J Manag Care Spec Pharm.
6 Chan B, Goldman LE, Sarkar U, et al. (2015). The Effect of a Care Transition Intervention on the Patient Experience of Older Multi-Lingual Adults in the Safety Net: Results of a Randomized Controlled Trial. J Gen Intern Med.
7 Costa LL, Poe SS, Lee MC. (2011). Challenges in posthospital care: nurses as coaches for medication management. J Nurs Care Qual.
8 Delate T, Chester EA, Stubbings TW, et al. (2008). Clinical outcomes of a home-based medication reconciliation program after discharge from a skilled nursing facility. Pharmacotherapy.
9 Dhalla IA, O'Brien T, Morra D, et al. (2014). Effect of a postdischarge virtual ward on readmission or death for high-risk patients: a randomized clinical trial. JAMA.
10 Farley TM, Shelsky C, Powell S, et al. (2014). Effect of clinical pharmacist intervention on medication discrepancies following hospital discharge. Int J Clin Pharm.
11 Feltner C, Jones CD, Cene CW, et al. (2014). Transitional care interventions to prevent readmissions for persons with heart failure: a systematic review and meta-analysis. Ann Intern Med.
12 Goldman LE, Sarkar U, Kessell E, et al. (2014). Support from hospital to home for elders: a randomized trial. Ann Intern Med.
13 Gurwitz JH, Field TS, Ogarek J, et al. (2014). An electronic health record-based intervention to increase follow-up office visits and decrease rehospitalization in older adults. J Am Geriatr Soc.
14 Hawes EM, Maxwell WD, White SF, et al. (2014). Impact of an outpatient pharmacist intervention on medication discrepancies and health care resource utilization in posthospitalization care transitions. J Prim Care Community Health.
15 Hesselink G, Schoonhoven L, Barach P, et al. (2012). Improving patient handovers from hospital to primary care: a systematic review. Ann Intern Med.
16 Kind AJH. (2013). Nurse Case Managers Offer Low-Resource Transitional Care Services, Reducing Readmissions for At-Risk, Community-Dwelling Veterans in Remote Areas. Service Delivery Innovation Profile.
17 LaMantia MA, Scheunemann LP, Viera AJ, et al. (2010). Interventions to improve transitional care between nursing homes and hospitals: a systematic review. J Am Geriatr Soc.
18 Lindquist LA, Yamahiro A, Garrett A, et al. (2013). Primary care physician communication at hospital discharge reduces medication discrepancies. J Hosp Med.
19 McGaw J, Conner DA, Delate TM, et al. (2007). A multidisciplinary approach to transition care: a patient safety innovation study. Perm J.
20 Moyer VA, Papile LA, Eichenwald E, et al. (2014). An intervention to improve transitions from NICU to ambulatory care: quasi-experimental study. BMJ Qual Saf.
21 Nazar H, Nazar Z, Portlock J, et al. (2015). A systematic review of the role of community pharmacies in improving the transition from secondary to primary care. Br J Clin Pharmacol.
22 Ostrovsky A. (2014). Community-Based Health Coaches and Care Coordinators Reduce Readmissions Using Information Technology To Identify and Support At-Risk Medicare Patients After Discharge. Service Delivery Innovation Profile.
23 Paquin AM, Salow M, Rudolph JL. (2015). Pharmacist calls to older adults with cognitive difficulties after discharge in a Tertiary Veterans Administration Medical Center: a quality improvement program. J Am Geriatr Soc.
24 Rennke S, Nguyen OK, Shoeb MH, et al. (2013). Hospital-initiated transitional care interventions as a patient safety strategy: a systematic review. Ann Intern Med.
25 Rice YB, Barnes CA, Rastogi R, et al. (2015). Tackling 30-day, All-Cause Readmissions With a Patient-Centered Transitional Care Bundle. Popul Health Manag.
26 Rosenbek S. (2008). Transition Coaches Reduce Readmissions for Medicare Patients With Complex Postdischarge Needs. Service Delivery Innovation Profile.
27 Setter SM, Corbett CF, Neumiller JJ, et al. (2009). Effectiveness of a pharmacist-nurse intervention on resolving medication discrepancies for patients transitioning from hospital to home health care. Am J Health Syst Pharm.
28 Spinewine A, Claeys C, Foulon V, et al. (2013). Approaches for improving continuity of care in medication management: a systematic review. Int J Qual Health Care.
29 Tuso P, Huynh DN, Garofalo L, et al. (2013). The readmission reduction program of Kaiser Permanente Southern California-knowledge transfer and performance improvement. Perm J.
30 Voss R, Gardner R, Baier R, et al. (2011). The care transitions intervention: translating from efficacy to effectiveness. Arch Intern Med.