# Appendix C Table of Themes in Key Informant Discussions

Table C1 Safety Practices

| KI-A | KI-B | KI-C | KI-D | KI-E | KI-F | KI-G
Communication | CROSS-CUTTING VULNERABILITY Administrative and Communication Errors^*^ | | | PCMH has better communication built in which may promote safety
HIT | Underpinning infrastructure that is increasingly in so much of what we do, but it is not a panacea or “magic bullet.”; - alert fatigue; - work-arounds | We are replicating old ways of doing things in an electronic format rather than transforming the way we do things | | | | - Poor EHR usability exacerbating burnout; - GAP: EHR optimization to improve safety | HIEs not implemented meaningfully yet. Still with unprocessed data that is not usable to clinicians in real-time, not helping loops be closed.
Teams | Skill mix promotes safety | - Can extrapolate from inpatient that nurse staffing might help; - NPs may be underutilized | | PCMH has teams and this may promote safety
Patient Engagement | | Need to make much bigger strides in terms of: patient engagement, shared decision making, thinking about how behavior changed theory needs to underpin the patient, clinician and organization | Patient more important in outpatient setting | | Lack of patient education, such as medication treatment adherence, for instance if a patient is on warfarin or another medication that needs monitoring | Includes health literacy
Organizational Approaches | - Care coordination; - Regular monitoring, appraisals and benchmarking across primary care sites | - Burnout pervasive and unsafe^*^ | | - PCMH; - Needed study: examine whether/ how PCMH improves safety | Care contained within a single system (information flow) important for safety | - Need to study burnout and safety; - Current lack of infrastructure/ skills: there needs to be infrastructure in place to implement it, such as expertise around QI, around process redesign, around doing root cause analyses, around safety reporting, and is there a mechanism for staff to report issues, etc. If something bad happens in the practice, do they know about it and, if so, do they have the knowledge, expertise, and tools to think about it from a systems perspective and do a root cause analysis or whatever is needed to design an improvement. PCMH often includes this.; - PSOs have potential esp b/c peer review protection and potential for feedback, though not fully realized.
Measurement | Needs adequate baselining and triangulation- single measurement approach will always under-estimate, need to include patient and caregiver reports. | Measurement is not the same as improvement. Source of frustration if there's no mechanism to improve. | | | | | Current lack of validated measures is a barrier to improvement^*^

* indicates agreement/mention by another person

Table C2 Prescribing and Medication Errors - “low-hanging fruit”

| KI-A | KI-B | KI-C | KI-D | KI-E | KI-F | KI-G
Strategy | Problems can be the actual prescription being issued at the time, drug interaction or morbidity, and contraindications. monitoring of certain classes of drugs, such as lithium, ACE inhibitors, and electrolytes.; - quality not safety, such as drugs not being taken as intended or adherence^*^ | | - Opioids, anticoagulation, insulin (Natl Action Plan)- funding specifically for these.; - Antibiotic stewardship (safety or quality); - Unsupervised child ingestions; - Most harm occurs in monitoring. Formative work needed re: opioids: how does it relate to medication safety more broadly? What interventions beyond addressing obvious errors and abuse prevention would work? Kaveh's comparison to abx stewardship flawed per Dan b/c easier to establish need for abx than need for pain meds. | | | Allergy documentation | Should include medication dispensing, including dispensing of meds MD has stopped
Communication | | | Changes made to the prescription writing so that it is consistent, from the electronic order entry screen to the pharmacy to the bottle.
HIT | Intervention: decision support | | Changes made to the prescription writing so that it is consistent, from the electronic order entry screen to the pharmacy to the bottle.
Teams | Intervention: Pharmacist on team (PINCER trial, now in practice in UK-PharmDs identify and rectify errors)
Organizational approaches | Intervention: Prescribing checklist | | Current systems don't support ongoing monitoring well | | Need to educate patients about self-management of meds

* indicates agreement/mention by another person

Table C3 Diagnostic Errors

| KI-A | KI-B | KI-C | KI-D | KI-E | KI-F | KI-G
Strategy | Includes wrong diagnoses, missed diagnoses, not appropriately stratifying patients within a diagnosis and then the whole chain of problems that can ensue subsequently; - Rare/serious undifferentiated conditions with limited window for action (meningitis, stroke) | | | | Martine: need to prioritize dx | Cognitive error and well as test result management, referral management and all of those pieces. | Need primary data collection around diagnosis^*^
Communication | Three-way consultation amongst specialists
HIT | Intervention: decision support
Organizational approaches | Intervention: ready access to real time investigative procedures in house in ambulatory care, such as ultrasound, CT, or MRI or second opinions (being institutionalized at KP) | | | | Martine added about diagnostic errors that it is not being tracked or reported and physicians and patients aren't really informed about what it is, where it occurs most often and they aren't given tools to help prevent it or to help assist a more accurate diagnosis, and if there is not an accurate diagnosis, how is there going to be an accurate treatment plan?

* indicates agreement/mention by another person

Table C4 Transitions/boundaries

| KI-A | KI-B | KI-C | KI-D | KI-E | KI-F | KI-G
Strategy | In/ out hospital, primary care and other ambulatory care and another big one is the social care dimension, long term care or post-acute care sector; - Multi-morbidity (when recommendations and treatments for one condition adversely affect another)
Communication | Need for synchronous communication when patient transitions
HIT | | | | | | | Interoperability needed
Teams | | | | Needed intervention: Make sure information moves with patient during transitions
Patient-engagement | “Wider issues as to the kinds of messages the patients are taking away, particularly in chronic disorders where this is absolutely fundamental because ideally we want the generalist, the specialist and the patient to all be on the same page and not to be speaking as cross purposes.”; - Self-care agenda, considering patients are caring for themselves 98-99% of their lives

Table C5 Referrals

| KI-A | KI-B | KI-C | KI-D | KI-E | KI-F | KI-G
Strategy | | How are we insuring that they're getting to the right people for the right things and getting that follow-up and continuity? We have a lot of perverse incentives
Organizational approaches | | Perverse financial incentives can interfere with referrals | | | | | - Unclear referral reasons. Provider only has a sense of what's wrong with them about half the time and many of the referrals end up not getting closed. When we look at our malpractice cases many are issues in which the primary care provider did recognize there was an issue and did try to send someone to another provider, but there was an incomplete path. Systems just really haven't developed good approaches for managing that

Table C6 Culture

| KI-A | KI-B | KI-C | KI-D | KI-E | KI-F | KI-G
Strategy | | Fear/ Inability to speak up: when someone knows that something isn't quite right and they can't figure out how to get that addressed, whether it is a patient who doesn't want to ask questions or doesn't feel comfortable doing it or a provider, medical assistant, new doctor, or nurse that understands that something isn't quite right in a situation, but can't figure out how to get that resolved
Organizational approaches | | | | Complacency: we need to move from “I just have a really crappy system for that” or “nobody worries about that” to the fact that “yes, I have a really bad EHR and it is causing safety problems for my practice and my patients.” What keeps her up is how we move people further along that line.

Table C7 Testing process^*^

| KI-A | KI-B | KI-C | KI-D | KI-E | KI-F | KI-G
Strategy | | | | Ordering the wrong tests, poor interpretation of tests, not notifying patients of test results, and most importantly not following up of important, urgent, abnormal or normal that shouldn't be normal test results with patients.
Organizational approaches | | | | Lack of system for the testing process in current systems

* indicates agreement/mention by another person

Table C8 General Comments

| KI-A | KI-B | KI-C | KI-D | KI-E | KI-F | KI-G
Formative scientific work | DIAGNOSTIC ERRORS Dx errors need formative science | | DIAGNOSTIC ERRORS and PRIORITIZATION Problems which are frequent, serious, measureable and feasibly prevented
Intervention development | Need to focus on intervention development process-MRC's complex intervention framework for developing interventions – appropriate systematic review evidence, theory, feasibility testing, piloting, randomized controlled trials – and then scaling up. We recognize the kind of errors that most frequently translate into harm – a subset of drugs that are particularly important, a subset of diagnostic errors that are particularly important – and so in those areas really catalyzing the development of interventions.
| KI-A believes in collaborative models and the way he would do it is to develop a network with a view to intervention development. Appropriate conceptualization and looking at the theoretical dimensions is important and then another big charge with a complex intervention is the generalizability piece. Two processes
| 1. Pre-specifying and honing in on specific, high-yield issues and moving from intervention development to RCTs; 2. If targeting a broad PSP like improving cognition, use other kinds of evaluations quite a lot of the time, and so it may it may be more program-matic where you might move into a QI kind of approach for quality improvement.
Interdisciplinary | | Need the broad, interdisciplinary theoretical work to drive improvement: bringing together and sparking creativity across disciplines, including design; cognitive support – how do we better address some of those other components that would ultimately be part of the safest possible care.

* indicates agreement/mention by another person