# Appendix A Search Methodology

## PATIENT SAFETY IN AMBULATORY CARE

The search methodologies included here are by topic:

### DIAGNOSTIC ERRORS

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/11/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

“Diagnostic Errors”[Mesh] OR diagnostic error* OR misdiagnos* OR false positive* OR false negative* OR “errors in diagnosis”

NUMBER OF RESULTS: 1998

==========================================================================

### E-PRESCRIBING

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/4/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

e-prescription* OR e-prescrib* OR electronic prescription* OR electronic prescrib*

NUMBER OF RESULTS: 481

==========================================================================

### HAND HYGIENE

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/10/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

“Hand Hygiene”[Mesh] OR ((hand OR hands) AND (hygien* OR wash OR washing OR disinfect*))

NUMBER OF RESULTS: 80

==========================================================================

### HEALTH LITERACY

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/7/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

“Health Literacy”[Mesh] OR “health literacy”[tiab] OR patient educat*

NUMBER OF RESULTS: 1172

==========================================================================

### HUMAN FACTORS

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/10/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

“Human Engineering”[Mesh] OR human factor* OR ergonomic*

NUMBER OF RESULTS: 264

==========================================================================

### INFECTION CONTROL

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/10/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

“Infection Control”[Mesh] OR “Infection Control Practitioners”[Mesh] OR (infection* AND (prevent OR prevents OR preventing OR prevention OR control OR controlling OR Controlled))

NUMBER OF RESULTS: 2271

==========================================================================

### INFORMED CONSENT

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-7/30/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error* OR safety management

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

“Informed Consent”[Mesh] OR “informed consent”[tiab]

NUMBER OF RESULTS: 228

==========================================================================

### JCAHO “DO NOT USE” LIST

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/10/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

joint commission OR jcaho

AND

“do not use” OR do-not-use OR abbreviation*

NUMBER OF RESULTS: 35

==========================================================================

### LIFE-SUSTAINING TREATMENT

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/10/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

“Advance Directives”[Mesh] OR “Resuscitation Orders”[Mesh] OR “life support” OR life sustain* OR advance directive* OR living will* OR “power of attorney” OR resuscitat* OR “do not resuscitate” OR “do-not-resuscitate”

NUMBER OF RESULTS: 366

==========================================================================

### MENTAL HEALTH

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/7/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

“Mental Health Services”[Mesh] OR “Mental Health”[Mesh] OR “Mental Disorders”[Mesh] OR mental health* OR mental* ill OR mental illness OR psychological health* OR psychosis OR psychotic* OR schizophren* OR bipolar

AND

integrated OR co-locat* OR primary care

NUMBER OF RESULTS: 490

==========================================================================

### MONITORING MEDICATIONS

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-7/30/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

monitor*[ti] OR reporting[ti]

AND

medication* OR medicine* OR pharmaceutical* OR prescription* OR drug OR drugs

NUMBER OF RESULTS: 377

==========================================================================

### MONITORING PATIENT SAFETY PROBLEMS

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/11/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

monitor* OR track*

AND

problem*

NUMBER OF RESULTS: 463

==========================================================================

### MULTIMORBIDITY

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/6/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

multimorbid* OR multi-morbid* OR multi morbid* OR complex patient* OR complex disease* OR complex condition* OR multiple chronic disease* OR multiple chronic condition* OR “Comorbidity”[Mesh] OR comorbid* OR co-morbid*

NUMBER OF RESULTS: 1381

==========================================================================

### OPIOID USE

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-7/30/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

opioid*

AND

use OR abus* OR addict* OR overuse OR over-use

NUMBER OF RESULTS: 207

==========================================================================

### PATIENT & FAMILY ENGAGEMENT

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/10/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

“Patient Participation”[Mesh] OR ((patient[ti] OR patients[ti] OR family[ti] OR families[ti] OR spouse*[ti] OR consumer* OR caregiver*) AND (engag* OR participat* OR involv* OR responsib*))

NUMBER OF RESULTS: 2096

==========================================================================

### PHARMACISTS' ROLE

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/11/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

“Pharmacists”[Mesh] OR clinical pharmac*

NUMBER OF RESULTS: 758

==========================================================================

### RADIATION EXPOSURE

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/11/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

“Radiation Injuries”[Mesh] OR “Radiography/adverse effects”[Mesh] OR

“Radiography/complications”[Mesh] OR “Radiography/contraindications”[Mesh] OR

“Radiography/radiation effects”[Mesh] OR radiation injur*[tiab] OR radiation expos*[tiab] OR

((radiation OR x-ray* OR x ray* OR xray* OR fluoroscop* OR tomograph*) AND (injury OR injuries OR harm* OR death OR mortality))

NUMBER OF RESULTS: 1136

==========================================================================

### REFERRALS

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/6/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

“Referral and Consultation”[Mesh] OR refer[ti] OR referring[ti] OR referral*[tiab] OR consult*[ti] OR consulting[tiab] OR gatekeep*[tiab] OR gate keep*[tiab] OR second opinion*

NUMBER OF RESULTS: 1389

==========================================================================

### SAFETY CULTURE

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/10/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care” OR “Outpatients”[Mesh] OR outpatient*[tiab]

AND

“Organizational Culture”[Mesh] OR organization* culture* OR organisation* culture OR corporate culture* OR shared value* OR “culture of safety” OR safety culture*

NUMBER OF RESULTS: 276

==========================================================================

### SELF-MANAGEMENT OF MEDICATIONS

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-7/30/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

self-manag* OR self manag*

AND

medication* OR medicine* OR pharmaceutical* OR prescription* OR drug OR drugs

NUMBER OF RESULTS: 279

==========================================================================

### SIMULATION

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-7/30/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error* OR safety management

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

simulation

NUMBER OF RESULTS: 447

==========================================================================

### TEAM-TRAINING

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-7/30/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

((team OR teams OR teamwork OR collaborat*) AND train*) OR team-training

NUMBER OF RESULTS: 358

==========================================================================

### TELEPHONE TRIAGE

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/6/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

triage

AND

telephone OR phone

NUMBER OF RESULTS: 60

==========================================================================

### TRACKING TEST RESULTS

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-7/30/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

screen* OR mass screening OR ((laboratory OR laboratories) AND (test OR tests OR testing))

AND

track* OR follow-up OR “follow up” OR follow* up OR notify* OR notification OR monitor* OR lost OR missed OR delay* OR correct OR incorrect OR wrong OR communicat* OR testing process*

AND

result OR results OR diagnosis OR diagnoses OR diagnostic

NUMBER OF RESULTS: 931

==========================================================================

### TRANSITIONS OTHER THAN HOSPITAL TO AMBULATORY CARE

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-7/30/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

transition* OR care coordinat* OR care co-ordinat* OR “coordination of care” OR “co-ordination of care”

NUMBER OF RESULTS: 482

==========================================================================

### TRANSITIONS AT HOSPITAL DISCHARGE

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-8/11/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

transition* OR care coordinat* OR care co-ordinat* OR “coordination of care” OR “co-ordination of care”

AND

“Patient Discharge”[Mesh] OR hospital discharg* OR patient discharg*[tiab] OR discharge plan*

NUMBER OF RESULTS: 253

==========================================================================

### WORKFORCE

#### DATABASE SEARCHED & TIME PERIOD COVERED

PubMed – 1/1/2000-7/30/2015

#### LANGUAGE

English

#### SEARCH STRATEGY

“Patient Safety”[Mesh] OR Safety management OR safety[tiab] OR accident*[tiab] OR harm*[tiab] OR complication* OR error*

AND

“Ambulatory Care”[Mesh] OR “Ambulatory Care Facilities”[Mesh] OR ambulatory[tiab] OR nurse practitioner* OR minute-clinic* OR minute clinic* OR community pharmac* OR dentist* OR midwives OR midwife* OR hospice* OR telehealth OR telemedicine OR “home care”

AND

“job satisfaction” OR job dissatisf* OR workforce OR workload OR “safety culture” OR “culture of safety” OR handoff* OR hand-off* OR professional competence OR competen* OR whistleblower* OR retaliat* OR collaborat* OR “safety climate” OR “climate of safety” OR interrupt* OR work environment*

NUMBER OF RESULTS: 2756

FURTHER FILTERED IN ENDNOTE AS FOLLOWS:

ALL FIELDS:

- job satisfy*
- work stressor*
- staffing
- turnover*

- workplace
- culture
- interrup*
- safety climate
- workload
- handoff
- competen*
- whistleblower
- retaliate*

NUMBER OF RESULTS AFTER FILTERING: 1764