# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
IT: Information Technology
IOM: Institute of Medicine
KI(s): Key Informant(s)
PA-PSRS: Pennsylvania Patient Safety Authority Site
PCMH: Patient-Centered Medical Homes
PSP(s): Patient Safety Practice(s)
RCT: Randomized Controlled Trial
SR: Systematic Review
TOO: Task Order Officer