# References

1 Hetrick SE, Parker AG, Callahan P, et al. Evidence mapping: illustrating an emerging methodology to improve evidence-based practice in youth mental health. J Eval Clin Pract. Dec. 2010;16(6):1025-30. [doi: 10.1111/j.1365-2753.2008.01112.x]. [pmid: 20337833].
2 Bates S, Coren E. Systematic Map Report 1: The extent and impact of parental mental health problems on families and the acceptability, accessibility and effectiveness of interventions. London. Social Care Institute for Excellence. 2006. http://www.scie.org.uk/publications/map/map01.pdf. June 17, 2016.
3 Carr S, Clapton J. Systematic Map Report 2: The recovery approach in community-based vocation and training adult mental health day services. London. Social Care Institute for Excellence. 2007. http://www.scie.org.uk/publications/map/map02.pdf?res=true. June 17, 2016.
4 Sharif N, Brown W, Rutter D. Systematic Map Report 3: The extent and impact of depression on BME older people and the acceptability, accessability and effectiveness of social care provision. London. Social Care Institute for Excellence. 2008. http://www.scie.org.uk/publications/map/map03.pdf. June 17, 2016.
5 Coeytaux RR, McDuffie J, Goode A, et al. VA Evidence-based Synthesis Program Reports. Evidence Map of Yoga for High-Impact Conditions Affecting Veterans. Washington, DC. Department of Veterans Affairs (US). 2014. [pmid: 25254284].
6 Hempel S, Taylor SL, Solloway MR, et al. Evidence Map of Acupuncture. VA Evidence-based Synthesis Program Reports. Washington, DC. Department of Veterans Affairs (US). 2014. [pmid: 24575449].
7 Hempel S, Taylor SL, Marshall NJ, et al. Evidence Map of Mindfulness. VA Evidence-based Synthesis Program Reports. Washington, DC. Department of Veterans Affairs (US). 2014. [pmid: 25577939].
8 Hempel S, Taylor SL, Solloway MR, et al. VA Evidence-based Synthesis Program Reports. Evidence Map of Tai Chi. Washington, DC. Department of Veterans Affairs (US). 2014.
9 Wang DD, Shams-White M, Bright OJ, et al. Creating a literature database of low-calorie sweeteners and health studies: evidence mapping. BMC Med Res Methodol. 2016;16(1):1. [doi: 10.1186/s12874-015-0105-z]. [pmid: 26728979].
10 Althuis MD, Weed DL. Evidence mapping: methodologic foundations and application to intervention and observational research on sugar-sweetened beverages and health outcomes. Am J Clin Nutr. Sep. 2013;98(3):755-68. [doi: 10.3945/ajcn.113.058917]. [pmid: 23824722].
11 McKinnon MC, Cheng SH, Garside R, et al. Sustainability: Map the evidence. Nature. Dec. 10. 2015;528(7581):185-7. [doi: 10.1038/528185a]. [pmid: 26659166].
12 Zundel KM. Telemedicine: history, applications, and impact on librarianship. Bull Med Libr Assoc. 1996;84(1):71-9. [pmid: 8938332].
13 HRSA. Telehealth. 2015. http://www.hrsa.gov/ruralhealth/telehealth/. June 17, 2016.
14 HealthIT.gov. What is telehealth? How is telehealth different from telemedicine?. http://www.healthit.gov/providers-professionals/faqs/what-telehealth-how-telehealth-different-telemedicine. March 9, 2015.
15 van Dyk L. A review of telehealth service implementation frameworks. Int J Environ Res Public Health. Feb. 2014;11(2):1279-98. [doi: 10.3390/ijerph110201279]. [pmid: 24464237].
16 Lustig T. The Role of Telehealth in an Evolving Health Care Environment - Workshop Summary. Washington, DC. Institute of Medicine. 2012.
17 Nelson B, Thune J. Letter to Richard Kronick, Agency for Healthcare Research and Quality. December. 30. 2014.
18 Multistakeholder Letter to Senate Committee on Aging. 2015. http://www.tiaonline.org/sites/default/files/pages/Multistakeholder%20Letter%20to%20Senate%20Ageing%20re%20AHRQ%20Lit%20Review%20120514.pdf. August 28, 2015.
19 Bashshur RL. Guest editorial: compelling issues in telemedicine. Telemed J E Health. May. 2013;19(5):330-2. [doi: 10.1089/tmj.2013.9998]. Epub 2013 Feb 5. [pmid: 23384331].
20 Dixon B, Hook J, McGowan J. Using Telehealth to Improve Quality and Safety: Findings from the AHRQ Health IT Portfolio. (Prepared by the AHRQ National Resource Center for Health IT under Contract No. 290-04-0016). AHRQ Publication No. 09-0012-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2008.
21 Roundtable: Harnessing the Power of Telehealth: Promises and Challenges? Testimony from Participants. Washington, DC. United States Senate Special Committee on Aging. 2014. http://www.aging.senate.gov/hearings/roundtable-harnessing-the-power-of-telehealth-promises-and-challenges. August 25, 2015.
22 The Role of Telehealth in an Evolving Health Care Environment: Workshop Summary. Washington, DC. The National Academies Press. 2012.
23 Adler-Milstein J, Kvedar J, Bates DW. Telehealth among US hospitals: several factors, including state reimbursement and licensure policies, influence adoption. Health Aff (Millwood). Feb. 2014;33(2):207-15. [doi: 10.1377/hlthaff.2013.1054]. [pmid: 24493762].
24 Broderick A, Lindeman D. Scaling Telehealth Programs: Lessons from Early Adopters. New York, NY. Commonwealth Fund. 2013. http://www.commonwealthfund.org/Publications/Case-Studies/2013/Jan/Telehealth-Synthesis.aspx. August 24, 2015.
25 Dinesen B, Nonnecke B, Lindeman D, et al. Personalized telehealth in the future: a global research agenda. J Med Internet Res. 2016;18(3):e53. [doi: 10.2196/jmir.5257]. [pmid: 26932229].
26 Hersh WR, Hickam DH, Severance SM, et al. Diagnosis, access and outcomes: update of a systematic review of telemedicine services. J Telemed Telecare. Suppl 2. 2006;12:S3-31. [doi: 10.1258/135763306778393117]. [pmid: 16989671].
27 Medicare Payment Advisory Commission. Public Meeting. March 3, 2016. http://www.medpac.gov/documents/0316_meeting_transcript.pdf?sfvrsn=0. June 17, 2016.
28 Schwamm LH. Telehealth: seven strategies to successfully implement disruptive technology and transform health care. Health Aff (Millwood). Feb. 2014;33(2):200-6. [doi: 10.1377/hlthaff.2013.1021]. [pmid: 24493761].
29 Kvedar J, Coye MJ, Everett W. Connected health: a review of technologies and strategies to improve patient care with telemedicine and telehealth. Health Aff (Millwood). Feb. 2014;33(2):194-9. [doi: 10.1377/hlthaff.2013.0992]. [pmid: 24493760].
30 Clapton J, Rutter D, Sharif N. SCIE Systematic Mapping Guidance. London. Social Care Institute for Excellence. 2009.
31 Bragge P, Clavisi O, Turner T, et al. The Global Evidence Mapping Initiative: scoping research in broad topic areas. BMC Med Res Methodol. 2011;11:92. [doi: 10.1186/1471-2288-11-92]. [pmid: 21682870].
32 Snilstveit B, Vojtkova M, Bhavsar A, et al. Evidence gap maps--a tool for promoting evidence-informed policy and prioritizing future research. World Bank Policy Research Working Paper, Report Number WPS6725. Washington, DC. The World Bank Group. 2013.
33 Miake-Lye IM, Hempel S, Shanman R, et al. What is an evidence map? A systematic review of published evidence maps and their definitions, methods, and products. Syst Rev. 2016;5(1):28. [doi: 10.1186/s13643-016-0204-x]. [pmid: 26864942].
34 National Research Council. Finding What Works in Health Care: Standards for Systematic Reviews. Washington, DC. The National Academies Press. 2011.
35 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(13)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2014.
36 Nelson H. Systematic Reviews to Answer Health Care Questions. Philadelphia, PA. Wolters Kluwer. 2014.
37 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-20. [doi: 10.1016/j.jclinepi.2008.10.009]. [pmid: 19230606].
38 Ammenwerth E, Schnell-Inderst P, Hoerbst A. The impact of electronic patient portals on patient care: a systematic review of controlled trials. J Med Internet Res. 2012;14(6):e162. [doi: 10.2196/jmir.2238]. [pmid: 23183044].
39 Antonacci DJ, Bloch RM, Saeed SA, et al. Empirical evidence on the use and effectiveness of telepsychiatry via videoconferencing: implications for forensic and correctional psychiatry. Behav Sci Law. 2008;26(3):253-69. [doi: 10.1002/bsl.812]. [pmid: 18548519].
40 Antoniou SA, Antoniou GA, Franzen J, et al. A comprehensive review of telementoring applications in laparoscopic general surgery. Surg Endosc. Aug. 2012;26(8):2111-6. [doi: 10.1007/s00464-012-2175-x]. [pmid: 22350150].
41 Chaudhry SI, Phillips CO, Stewart SS, et al. Telemonitoring for patients with chronic heart failure: a systematic review. J Card Fail. Feb. 2007;13(1):56-62. [pmid: 17339004].
42 Clarke M, Shah A, Sharma U. Systematic review of studies on telemonitoring of patients with congestive heart failure: a meta-analysis. J Telemed Telecare. 2011;17(1):7-14. [doi: 10.1258/jtt.2010.100113]. [pmid: 21097564].
43 Connelly J, Kirk A, Masthoff J, et al. The use of technology to promote physical activity in Type 2 diabetes management: a systematic review. Diabet Med. Dec. 2013;30(12):1420-32. [doi: 10.1111/dme.12289]. [pmid: 23870009].
44 Cox NS, Alison JA, Rasekaba T, et al. Telehealth in cystic fibrosis: a systematic review. J Telemed Telecare. Mar. 2012;18(2):72-8. [doi: 10.1258/jtt.2011.110705]. [pmid: 22198961].
45 Dang S, Dimmick S, Kelkar G. Evaluating the evidence base for the use of home telehealth remote monitoring in elderly with heart failure. Telemed J E Health. Oct. 2009;15(8):783-96. [doi: 10.1089/tmj.2009.0028]. [pmid: 19831704].
46 de Jong CC, Ros WJ, Schrijvers G. The effects on health behavior and health outcomes of Internet-based asynchronous communication between health providers and patients with a chronic condition: a systematic review. J Med Internet Res. 2014;16(1):e19. [doi: 10.2196/jmir.3000]. [pmid: 24434570].
47 de Waure C, Cadeddu C, Gualano MR, et al. Telemedicine for the reduction of myocardial infarction mortality: a systematic review and a meta-analysis of published studies. Telemed J E Health. Jun. 2012;18(5):323-8. [doi: 10.1089/tmj.2011.0158]. [pmid: 22468983].
48 Eccleston C, Fisher E, Craig L, et al. Psychological therapies (Internet-delivered) for the management of chronic pain in adults. Cochrane Database Syst Rev. 2014;2. CD010152. [doi: 10.1002/14651858.CD010152.pub2]. [pmid: 24574082].
49 Eland-de Kok P, van Os-Medendorp H, Vergouwe-Meijer A, et al. A systematic review of the effects of e-health on chronically ill patients. J Clin Nurs. Nov. 2011;20(21-22):2997-3010. [doi: 10.1111/j.1365-2702.2011.03743.x]. [pmid: 21707807].
50 Gaikwad R, Warren J. The role of home-based information and communications technology interventions in chronic disease management: a systematic literature review. Health Informatics J. Jun. 2009;15(2):122-46. [doi: 10.1177/1460458209102973]. [pmid: 19474225].
51 Gainsbury S, Blaszczynski A. A systematic review of Internet-based therapy for the treatment of addictions. Clin Psychol Rev. Apr. 2011;31(3):490-8. [doi: 10.1016/j.cpr.2010.11.007]. [pmid: 21146272].
52 Garcia-Lizana F, Sarria-Santamera A. New technologies for chronic disease management and control: a systematic review. J Telemed Telecare. 2007;13(2):62-8. [pmid: 17359568].
53 Holtz B, Lauckner C. Diabetes management via mobile phones: a systematic review. Telemed J EHealth. Apr. 2012;18(3):175-84. [doi: 10.1089/tmj.2011.0119]. [pmid: 22356525].
54 Hailey D, Roine R, Ohinmaa A, et al. Evidence on the effectiveness of telerehabilitation applications. Alberta, Canada. Institute of Health Economics. 2010. http://www.ihe.ca/publications/evidence-on-the-effectiveness-of-telerehabilitation-applications. June 17, 2016.
55 Jaana M, Pare G, Sicotte C. Home telemonitoring for respiratory conditions: a systematic review. Am J Manag Care. May. 2009;15(5):313-20. [pmid: 19435399].
56 Johansen MA, Berntsen GKR, Schuster T, et al. Electronic symptom reporting between patient and provider for improved health care service quality: a systematic review of randomized controlled trials. part 2: methodological quality and effects. J Med Internet Res. 2012;14(5):e126. [doi: 10.2196/jmir.2216]. [pmid: 23032363].
57 Kairy D, Lehoux P, Vincent C, et al. A systematic review of clinical outcomes, clinical process, healthcare utilization and costs associated with telerehabilitation. Disabil Rehabil. 2009;31(6):427-47. [doi: 10.1080/09638280802062553]. [pmid: 18720118].
58 Kamei T, Yamamoto Y, Kajii F, et al. Systematic review and meta-analysis of studies involving telehome monitoring-based telenursing for patients with chronic obstructive pulmonary disease. Jpn J Nurs Sci. Dec. 2013;10(2):180-92. [doi: 10.1111/j.1742-7924.2012.00228.x]. [pmid: 24373441].
59 Knowles SR, Mikocka-Walus A. Utilization and efficacy of internet-based eHealth technology in gastroenterology: a systematic review. Scand J Gastroenterol. Apr. 2014;49(4):387-408. [doi: 10.3109/00365521.2013.865259]. [pmid: 24494974].
60 Kodama S, Saito K, Tanaka S, et al. Effect of Web-based lifestyle modification on weight control: a meta-analysis. Int J Obesity. May. 2012;36(5):675-85. [doi: 10.1038/ijo.2011.121]. [pmid: 21694698].
61 Kumar G, Falk DM, Bonello RS, et al. The costs of critical care telemedicine programs: a systematic review and analysis. Chest. Jan. 2013;143(1):19-29. [pmid: 22797291].
62 Laver KE, Schoene D, Crotty M, et al. Telerehabilitation services for stroke. Cochrane Database Syst Rev. 2013;12. CD010255. [doi: 10.1002/14651858.CD010255.pub2]. [pmid: 24338496].
63 Liang X, Wang Q, Yang X, et al. Effect of mobile phone intervention for diabetes on glycaemic control: a meta-analysis. Diabet Med. Apr. 2011;28(4):455-63. [doi: 10.1111/j.1464-5491.2010.03180.x]. [pmid: 21392066].
64 Lustria MLA, Noar SM, Cortese J, et al. A meta-analysis of web-delivered tailored health behavior change interventions. [Erratum appears in J Health Commun. 2013;18(11):1397]. J Health Commun. 2013;18(9):1039-69. [doi: 10.1080/10810730.2013.768727]. [pmid: 23750972].
65 Martin S, Sutcliffe P, Griffiths F, et al. Effectiveness and impact of networked communication interventions in young people with mental health conditions: a systematic review. Patient Educ Couns. Nov. 2011;85(2):e108-19. [doi: 10.1016/j.pec.2010.11.014]. [pmid: 21239133].
66 McLean S, Nurmatov U, Liu JL, et al. Telehealthcare for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2011;(7). CD007718. [doi: 10.1002/14651858.CD007718.pub2]. [pmid: 21735417].
67 Merriel SWD, Andrews V, Salisbury C. Telehealth interventions for primary prevention of cardiovascular disease: a systematic review and meta-analysis. Prev Med. Jul. 2014;64:88-95. [doi: 10.1016/j.ypmed.2014.04.001]. [pmid: 24726502].
68 Peeters JM, Mistiaen P, Francke AL. Costs and financial benefits of video communication compared to usual care at home: a systematic review. J Telemed & Telecare. 2011;17(8):403-11. [doi: 10.1258/jtt.2011.110405]. [pmid: 22025744].
69 Ramadas A, Quek KF, Chan CKY, et al. Web-based interventions for the management of type 2 diabetes mellitus: a systematic review of recent evidence. Int J Med Inform. Jun. 2011;80(6):389-405. [doi: 10.1016/j.ijmedinf.2011.02.002]. [pmid: 21481632].
70 Richards D, Richardson T. Computer-based psychological treatments for depression: a systematic review and meta-analysis. Clin Psychol Rev. Jun. 2012;32(4):329-42. [doi: 10.1016/j.cpr.2012.02.004]. [pmid: 22466510].
71 Rietdijk R, Togher L, Power E. Supporting family members of people with traumatic brain injury using telehealth: a systematic review. J Rehabil Med. Nov. 5. 2012;44(11):913-21. [doi: 10.2340/16501977-1058]. [pmid: 23027316].
72 Rooke S, Thorsteinsson E, Karpin A, et al. Computer-delivered interventions for alcohol and tobacco use: a meta-analysis. Addiction. Aug. 2010;105(8):1381-90. [doi: 10.1111/j.1360-0443.2010.02975.x]. [pmid: 20528806].
73 Seto E. Cost comparison between telemonitoring and usual care of heart failure: a systematic review. Telemed J E Health. Sep. 2008;14(7):679-86. [doi: 10.1089/tmj.2007.0114]. [pmid: 18817497].
74 Steel K, Cox D, Garry H. Therapeutic videoconferencing interventions for the treatment of long-term conditions. J Telemed Telecare. 2011;17(3):109-17. [doi: 10.1258/jtt.2010.100318]. [pmid: 21339304].
75 Tan K, Lai NM. Telemedicine for the support of parents of high-risk newborn infants. Cochrane Database Syst Rev. 2012;6. CD006818. [doi: 10.1002/14651858.CD006818.pub2]. [pmid: 22696360].
76 Tran K, Polisena J, Coyle D, et al. Home Telehealth for Chronic Disease Management. (Technology report number 113). Ottawa, Canada. Canadian Agency for Drugs and Technologies in Health. 2008. https://www.cadth.ca/media/pdf/H0475_Home_Telehealth_tr_e.pdf. June 17, 2016.
77 Urquhart C, Currell R, Harlow F, et al. Home uterine monitoring for detecting preterm labour. Cochrane Database Syst Rev. 2015;(1). [pmid: 25558862].
78 Wade VA, Karnon J, Elshaug AG, et al. A systematic review of economic analyses of telehealth services using real time video communication. BMC Health Serv Res. 2010;10:233. [doi: 10.1186/1472-6963-10-233]. [pmid: 20696073].
79 Wallace DL, Hussain A, Khan N, et al. A systematic review of the evidence for telemedicine in burn care: with a UK perspective. Burns. Jun. 2012;38(4):465-80. [doi: 10.1016/j.burns.2011.09.024]. [pmid: 22078804].
80 Zhai Y-k, Zhu W-j, Cai Y-l, et al. Clinical- and cost-effectiveness of telemedicine in type 2 diabetes mellitus: a systematic review and meta-analysis. Medicine. Dec. 2014;93(28):e312. [doi: 10.1097/MD.0000000000000312]. [pmid: 25526482].
81 Conway A, Inglis SC, Clark RA. Effective technologies for noninvasive remote monitoring in heart failure. Telemed J E Health. Jun. 2014;20(6):531-8. [doi: 10.1089/tmj.2013.0267]. [pmid: 24731212].
82 Clark RA, Conway A, Poulsen V, et al. Alternative models of cardiac rehabilitation: a systematic review. Eur J Prev Cardiol. Jan. 2015;22(1):35-74. [doi: 10.1177/2047487313501093]. [pmid: 23943649].
83 Cruz J, Brooks D, Marques A. Home telemonitoring effectiveness in COPD: a systematic review. Int J Clin Pract. Mar. 2014;68(3):369-78. [doi: 10.1111/ijcp.12345]. [pmid: 24472009].
84 Devi R, Singh SJ, Powell J, et al. Internet-based interventions for the secondary prevention of coronary heart disease. Cochrane Database Syst Rev. 2015;(12). [pmid: 26691216].
85 dos Santos MT, Moura SC, Gomes LM, et al. Telehealth application on the rehabilitation of children and adolescents. Rev Paul Pediatr. Mar. 2014;32(1):136-43. [pmid: 24676201].
86 Flodgren G, Rachas A, Farmer AJ, et al. Interactive telemedicine: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2015;(9). [pmid: 26343551].
87 Kotb A, Cameron C, Hsieh S, et al. Comparative effectiveness of different forms of telemedicine for individuals with heart failure (HF): a systematic review and network meta-analysis. PLoS ONE. [Electronic Resource]. 2015;10(2):e0118681. [doi: 10.1371/journal.pone.0118681]. [pmid: 25714962].
88 Moy MF, Ray A, Buckley BS. Techniques of monitoring blood glucose during pregnancy for women with pre-existing diabetes. Cochrane Database Syst Rev. 2015;(11). [pmid: 24782359].
89 Parthiban N, Esterman A, Mahajan R, et al. Remote Monitoring of Implantable Cardioverter-Defibrillators: A Systematic Review and Meta-Analysis of Clinical Outcomes. J Am Coll Cardiol. Jun. 23. 2015;65(24):2591-600. [doi: 10.1016/j.jacc.2015.04.029]. [pmid: 25983009].
90 Rooksby M, Elouafkaoui P, Humphris G, et al. Internet-assisted delivery of cognitive behavioural therapy (CBT) for childhood anxiety: systematic review and meta-analysis. J Anxiety Disord. Jan. 2015;29:83-92. [doi: 10.1016/j.janxdis.2014.11.006]. [pmid: 25527900].
91 Saffari M, Ghanizadeh G, Koenig HG. Health education via mobile text messaging for glycemic control in adults with type 2 diabetes: a systematic review and meta-analysis. Prim Care Diabetes. Dec. 2014;8(4):275-85. [doi: 10.1016/j.pcd.2014.03.004]. [pmid: 24793589].
92 Toma T, Athanasiou T, Harling L, et al. Online social networking services in the management of patients with diabetes mellitus: systematic review and meta-analysis of randomised controlled trials. Diabetes Res Clin Pract. Nov. 2014;106(2):200-11. [doi: 10.1016/j.diabres.2014.06.008]. [pmid: 25043399].
93 van Beugen S, Ferwerda M, Hoeve D, et al. Internet-based cognitive behavioral therapy for patients with chronic somatic conditions: a meta-analytic review. J Med Internet Res. 2014;16(3):e88. [doi: 10.2196/jmir.2777]. [pmid: 24675372].
94 Warshaw EM, Hillman YJ, Greer NL, et al. Teledermatology for diagnosis and management of skin conditions: a systematic review. J Am Acad Dermatol. Apr. 2011;64(4):759-72. [doi: 10.1016/j.jaad.2010.08.026]. [pmid: 21036419].
95 Widmer RJ, Collins NM, Collins CS, et al. Digital health interventions for the prevention of cardiovascular disease: a systematic review and meta-analysis. Mayo Clin Proc. Apr. 2015;90(4):469-80. [doi: 10.1016/j.mayocp.2014.12.026]. [pmid: 25841251].
96 American Telemedicine Association. Standards and Guidelines Working Groups. Washington, DC. The American Telemedicine Association. 2012. http://www.americantelemed.org/resources/telemedicine-practice-guidelines/standards-working-groups#.VeC0F_lVhHx. August 28, 2015.
97 Center for Connected Health Policy. State Telehealth Laws and Medicaid Program Policies: A Comprehensive Scan of the 50 States and District of Columbia. Sacramento. Public Health Institute Center for Connected Health Policy. 2015. http://cchpca.org/sites/default/files/resources/50%20State%20FINAL%20April%202016.pdf. June 17, 2016.
98 Center for Reviews and Dissemination. PROSPERO. 2015. http://www.crd.york.ac.uk/PROSPERO/. August 28, 2015.
99 Inglis SC, Clark RA, McAlister FA, et al. Structured telephone support or telemonitoring programmes for patients with chronic heart failure. Cochrane Database Syst Rev. 2010;(8). Cd007228. [doi: 10.1002/14651858.CD007228.pub2]. [pmid: 20687083].
100 Bashshur RL, Shannon GW, Tejasvi T, et al. The Empirical Foundations of Teledermatology: A Review of the Research Evidence. Telemed J E Health. 2015. Sep. 22. [doi: 10.1089/tmj.2015.0146]. [pmid: 26394022].
101 Fisher ES, McClellan MB, Safran DG. Building the path to accountable care. N Engl J Med. Dec. 29. 2011;365(26):2445-7. [doi: 10.1056/NEJMp1112442]. [pmid: 22204720].
102 Burwell SM. Setting value-based payment goals--HHS efforts to improve U.S. health care. N Engl J Med. Mar. 5. 2015;372(10):897-9. [doi: 10.1056/NEJMp1500445]. Epub 2015 Jan 26. [pmid: 25622024].
103 Medicare.gov. Hospital Compare: Hospital Value-Based Purchasing. https://www.medicare.gov/hospitalcompare/Data/hospital-vbp.html. October 29, 2015.
104 Chipps J, Brysiewicz P, Mars M. Effectiveness and feasibility of telepsychiatry in resource constrained environments? A systematic review of the evidence. Afr J Psychiatry. Jul. 2012;15(4):235-43. [doi: 10.4314/ajpsy.v15i4.30]. [pmid: 22829225].
105 Conway A, Inglis SC, Chang AM, et al. Not all systematic reviews are systematic: a meta-review of the quality of systematic reviews for non-invasive remote monitoring in heart failure. J Telemed Telecare. Sep. 2013;19(6):326-37. [doi: 10.1177/1357633X13503427]. [pmid: 24163297].
106 Elbert NJ, van Os-Medendorp H, van Renselaar W, et al. Effectiveness and cost-effectiveness of ehealth interventions in somatic diseases: a systematic review of systematic reviews and meta-analyses. J Med Internet Res. 2014;16(4):e110. [doi: 10.2196/jmir.2790]. [pmid: 24739471].
107 Jones KR, Lekhak N, Kaewluang N. Using mobile phones and short message service to deliver self-management interventions for chronic conditions: a meta-review. Worldviews Evid Based Nurs. Apr. 2014;11(2):81-8. [doi: 10.1111/wvn.12030]. [pmid: 24597522].
108 Mair FS, May C, O'Donnell C, et al. Factors that promote or inhibit the implementation of e-health systems: an explanatory systematic review. Bull WHO. May. 1. 2012;90(5):357-64. [doi: 10.2471/BLT.11.099424]. [pmid: 22589569].
109 McLean S, Sheikh A, Cresswell K, et al. The impact of telehealthcare on the quality and safety of care: a systematic overview. PLoS ONE. [Electronic Resource]. 2013;8(8):e71238. [doi: 10.1371/journal.pone.0071238]. [pmid: 23977001].
110 Morrison D, Wyke S, Agur K, et al. Digital asthma self-management interventions: a systematic review. J Med Internet Res. 2014;16(2):e51. [doi: 10.2196/jmir.2814]. [pmid: 24550161].
111 Ekeland AG, Bowes A, Flottorp S. Effectiveness of telemedicine: a systematic review of reviews. Int J Med Inform. Nov. 2010;79(11):736-71. [doi: 10.1016/j.ijmedinf.2010.08.006]. [pmid: 20884286].