# Methods

An evidence map combines a systematic approach to identifying the existing literature on a topic with a description of key characteristics of the evidence identified. While evidence maps use some elements of systematic review methodology, they are a type of rapid review, and by definition are not comprehensive and do not purport to provide a definitive synthesis of results across a body of evidence. Methodology and guidance for the creation of literature maps exist;30-32 however, there are currently no accepted standards for this type of abbreviated, descriptive review and a systematic review of evidence mapping confirmed that the exact content and approach vary based on the goals of the project.33

In order to achieve the objectives listed above and create an evidence map of systematic reviews about telehealth, we developed a protocol based on adaptations of widely accepted systematic review methods34-36 and after consulting with Key Informants (KIs) and the funding agency, AHRQ. The KIs and AHRQ provided valuable perspectives, but they are not responsible for the resulting protocol or report. The protocol was posted on the AHRQ Web site on August 11, 2015 (http://www.effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=2110).

## Discussions with Key Informants

A group of six KIs representing diverse perspectives, including policy, research, telehealth use, and practice, supplemented with representation from U.S. Senate staff, participated in interviews during the initial phase of the project. KIs are recruited to provide insight and offer opinions, but they are not authors of the report, they are not responsible for the content, and the report does not necessarily reflect their views. In addition to the initial consultation, KIs are offered the opportunity to comment on the draft report as part of the peer review process. The purpose of KI interviews varies depending on the project requirements. In technical briefs about topics with limited research evidence they may offer expert opinion. It this case the KI role was to identify the current major practice and policy issues surrounding telehealth. This information informed our searches and development of the review inclusion and exclusion criteria, and also guided the collection and presentation of descriptive information in the evidence map. Recognizing these issues was crucial to understanding how research evidence about telehealth could best be organized in order to support stakeholder decisionmaking.

During the interviews, KIs raised the following major points:

- KIs discussed the state of the field and the fact that the scope of a technical brief may not be sufficient to address all stakeholder needs.
- KIs were concerned that there is already a vast body of literature available, but much of it may be of low quality and therefore not useful for decisionmakers. At the same time, they noted that, in their opinion, there are a number of well-executed studies. They stressed that combining results across studies without considering the quality of the research of the individual studies may be the reason many systematic reviews fail to come to clear conclusions about the effectiveness of telehealth.
- KIs emphasized that enough detail about how telehealth is used, including for which type of patients and what situations telehealth is studied, needs to be included in the research evidence in order for it to inform decisions about payment, licensing, credentialing, and investment.
- KIs underscored the need for cost effectiveness and other health care utilization outcomes in addition to clinical effectiveness outcomes. They emphasized the need for data on effectiveness and cost as higher priority than data on more process-related outcomes such as acceptability of telehealth by providers, patient satisfaction, or implementation facilitators and barriers.

## Search Strategies

We searched Ovid MEDLINE^®^, the Cochrane Database of Systematic Reviews, and PROSPERO, looking for completed systematic reviews and for systematic reviews in process. We also identified reviews of reviews (sometimes referred to as umbrella reviews) and checked their reference lists against our list of identified reviews. Searches were limited to systematic reviews published in or after 2006 through the end of January 2016 with search date ranges ending in 2005 or later. This date (2006) was selected because it was deemed early enough to capture all relevant published systematic reviews and primary studies of current telehealth approaches and technologies, and it coincided with the publication date of a previous systematic review of telemedicine that our Evidence-based Practice Center performed.26 These dates were discussed with the KIs, who agreed that older evidence would have limited relevance for pending decisions.

After screening, assessing, and categorizing the reviews, we conducted additional searches in Ovid MEDLINE for primary studies using the same relevant inclusion criteria on topics not covered by included systematic reviews. Similarly, to identify grey literature reports that were essentially systematic reviews, we searched the New York Academy of Medicine Grey Literature database. We also searched the Websites of telehealth-related organizations and U.S. government agencies with involvement in telehealth. When reviewing reports by U.S. government agencies and telehealth organizations we searched for both reports that were similar in methodology and purpose to published systematic reviews as well as for products with objectives similar to this brief (i.e., describing the state of the evidence available to support decisions about telehealth). Our search strategies including a list of Web sites searched are included in Appendix A.

## Study Selection

We developed criteria for inclusion and exclusion of studies (first systematic reviews and then primary studies) based on the Guiding Questions and consideration of the current issues and questions raised by stakeholders. The ability of the research evidence to inform decisionmaking guided study eligibility criteria, influenced what information we collected, and shaped how we presented our findings. We adapted a standard framework used in systematic reviews referred to as PICOTS (population, intervention, comparators, outcomes, timing, and setting) to outline our eligibility criteria. Inclusion and exclusion criteria are detailed in Appendix B and are described in this section. A list of the included systematic reviews can be found in Appendix C; excluded reviews are listed in Appendix D.

Definition of telehealth interventions for this brief. As described in the introduction, telehealth can refer to the use of several different technologies for many purposes related to health care. In order to define a scope that corresponded to pressing policy questions and to be sure that we were summarizing evidence on comparable interventions (i.e., not comparing apples and oranges), we established a core definition for this brief that includes the use of interactive technology to provide health care for specific patients. For our purposes, for an intervention to be considered telehealth it had to include the use of technology to facilitate an interaction between a patient and the health care system or interaction between two or more providers when the interaction was directly related to an individual patient's care. The interaction could occur over distance and/or over time (asynchronous as opposed to in real time). Using this definition, telehealth includes using video or mobile devices to offer counseling (over distance and in real time), remote patient monitoring which uses a variety of technology to transmit patient physiologic data to providers who monitor the patient condition and adjust treatment when needed (over distance and asynchronous), or using technology to obtain a consultation from another provider (either in real time or asynchronous). Following a precedent set in previous studies, telephone-only voice conversations were not considered telehealth. E-mail and Short Message Service (SMS) text were considered to be telehealth if they were interactive and replaced an in-person interaction (i.e., automated text messaging was not included), but they were not included if they were only in one direction (e.g., notifications) or if they were not personalized (e.g., generic messages sent to a group of patients). This definition was applied to both systematic reviews and our later consideration of individual studies.

Study design and quality. Our core search was for systematic reviews that focused on telehealth and synthesized clinical or utilization/cost outcomes across primary research studies. The rationale for basing the map on systematic reviews is that systematic reviews are the pinnacle of the evidence hierarchy for informing decisions. In most cases changes in policy and practice are not based on a single study; rather they are based on a body of evidence consisting of several studies. Systematic reviews are by definition a means of assembling a body of evidence and making it more accessible to users than the individual studies on their own. A systematic review should identify, evaluate, and synthesize evidence, including drawing conclusions across studies about the effectiveness of interventions or explaining why such a conclusion could not be made. This corresponds to the main objective of the report, which is to identify telehealth topics for which sufficient evidence exists and topics for which either additional systematic reviews or additional primary studies are needed.

It is also important that included reviews be of high quality. We incorporated key elements of the AMSTAR checklist,37 one of several tools that can be used to assess the methodological quality of systematic reviews, into our inclusion criteria and analysis. Specifically, for a review to be considered “systematic” and included in our map it had to have 1) included a comprehensive literature search of one or more citation databases, 2) based study selection on prespecified inclusion and exclusion criteria, and 3) assessed the quality (or risk of bias) of individual studies included in the review. These correspond to three of the eleven AMSTAR criteria. Reviews that did not meet these criteria were excluded. Two additional AMSTAR criteria are included in our descriptions and analyses. We documented whether each review included a strength of evidence (SOE) assessment, which entails incorporating the quality of the individual studies and other explicitly stated criteria into a rating of the body of evidence. We also documented if meta-analysis were used to combine quantitative results. Incorporating these five criteria in this way allowed us to give significant weight to these criteria that were essential to our purpose and to use them in different ways in our descriptions and analyses that would not be possible if they were combined into a single AMSTAR score for each review. This does not mean the other criteria are not important nor that the score is not useful, rather in our design of an evidence map we decided to focus on these critical criteria and create a flexible approach that allowed us to use different criteria at different points in the process.

Outcomes. Included systematic reviews had to report clinical, resource utilization, or cost outcomes, corresponding to our interest in research on the effectiveness of telehealth in terms of patient-level outcomes. We did not include other outcomes such as patient or provider satisfaction with or attitudes toward telehealth or assessments of diagnostic accuracy or agreement when telehealth was used. We also excluded studies where the outcome was the extent or success of implementation

Population. We included reviews that included studies involving adults and/or children for whose care telehealth was used for prevention, diagnosis, or treatment for any health condition.

Timing. We did not restrict inclusion according to timing, length of the intervention, or length of followup. We included systematic reviews published in 2006 or later and that included a search with an end date in 2005 or later.

Setting. We did not restrict the location of either the provider or patient.

To identify potential studies, abstracts were reviewed by two investigators and full-text articles for all citations deemed appropriate for inclusion by at least one of the reviewers were retrieved. Full-text articles were reviewed for inclusion or exclusion by one investigator and confirmed by a second investigator. Discrepancies were resolved by discussion and consensus.

Included systematic reviews were grouped by clinical focus and telehealth function. These groupings were developed by the investigators based on the identified and included reviews. For this reason, they are listed and defined in the Results section of this brief.

We used these groupings to describe the literature and generate the tables and bubble plots that constitute our primary analysis. As a secondary analysis we then compared the topics covered by the included reviews to major topic areas in which telehealth interventions have been observed. For the topics not covered by our included systematic reviews, we first examined the topics covered by excluded reviews as a means of verifying the existence of studies that could be analyzed, and supplemented this with searches for primary research on the topics that were still not represented. We applied the same inclusion criteria related to the population, intervention, definition of telehealth, outcomes, time, and setting, but not study design, to identify potentially relevant primary research.

## Data Extraction and Data Management

After identifying the subset of systematic reviews that met our inclusion criteria, we extracted data from the reviews into tables. This included basic information (dates of search, number of included studies, number of included randomized controlled trials [RCTs]), information on the clinical focus area, study purpose, populations included, the function telehealth played in care, telehealth modality/technology, and two indicators of the rigor and type of analysis used in the review (i.e., was there a strength of evidence assessment and was a meta-analysis attempted?). To develop these tables, we started with a list of information of interest and tested it on selected included studies, and then refined and finalized the list to include what is reported in the identified systematic reviews on telehealth. See Appendixes E and F for data extraction tables. Additionally, we generated a list of the included studies and their sample sizes for each review (Appendix G). We used these lists to eliminate duplicate studies and avoid double counting when reporting the number of studies and patients in the included reviews within a clinical or functional area as indicators of the size of the evidence base.

## Data Synthesis: Generating an Evidence Map

An evidence map combines graphics, tables, and accompanying text. While the methodology for evidence maps is not standardized, by nature they involve a reductive approach to summarizing and presenting information. Evidence maps are not designed to be comprehensive, rather they present selected characteristics and they rely on categorization and grouping of information.

For our evidence map, the core graphics are two bubble plots and a figure. One bubble plot is organized by clinical focus of the telehealth interventions, while the other is organized by health care function. We selected these two categorizations because decisions about telehealth are usually made about its use with particular types of patients (clinical focus, e.g., patients with diabetes or heart failure) or to deliver a type of health care service (e.g., health care functions such as remote patient monitoring or psychotherapy). Each of the two bubble plots then convey four additional dimensions about the clinical focus or health care function categories: 1) number of studies included in reviews, 2) total sample sizes (e.g., the number of patients), 3) the general direction and strength of any reported effect, and 4) the percentage of the reviews that include strength of evidence assessment. A third figure presents how the clinical focus and function categories intersect. This creates groupings of the evidence that are more specific, for example it shows what evidence is available about telehealth for remote patient monitoring (function) for people with chronic conditions (clinical area). This figure reports for each grouping: 1) the number of included systematic reviews, 2) the number of studies in the reviews, and 3) the overall conclusion of each review.

To develop the clinical and function categories, team members first individually extracted the information from all the included reviews. Then team members met, reviewed the topics of the included reviews, and developed the categories for clinical focus and function through discussion and consensus. It is important to note that the categories for this descriptive analysis were derived from the literature and do not constitute a list of all possibilities for telehealth. For clinical focus the reviews included those with specific indications (e.g., diabetes) or more general clinical areas (e.g., behavioral health). For function we grouped the reviews by the service the telehealth intervention provided (e.g., monitoring and counseling). Each included systematic review was assigned to the one clinical focus and the one function category that best matched its content. The categories and their definitions are included in the Results below.

While both of these bubble plots represent the same group of systematic reviews we chose these two different approaches to organization and representation of the information as these correspond to the key types of decisionmaking identified by the Guiding Questions and the KIs. Policy and clinical decisions can be made based on the functional category (e.g., decisions about programs for monitoring chronic disease in the rural elderly), by a clinical area (e.g., support for specific interventions for patients with diabetes), or by combinations. The organization of the evidence in these plots and the figure are designed to assist users in determining if evidence exists about specific telehealth interventions and if this evidence can be used to inform decisions about telehealth for specific clinical focus areas and/or functions in health care delivery.

The individual bubbles in these plots represent the specific clinical area or function for which we found systematic review evidence that met our criteria. The other dimensions are the number of individual studies (indicated by the size of the bubble), the number of patients studied (represented on the y-axis), and a weighted estimate of the reported effect (represented on the x-axis). The first two characteristics required looking across reviews and determining which studies were in multiple reviews. The lists of studies included in each review were used to create a list of primary studies without duplicates. The number of patients in these studies and the number of unique studies were then aggregated by both clinical focus and function. In the figure that combines clinical focus and function, the number of studies reported is the total number in each review and therefore there are duplicates within the cells.

Creating a weighted way to summarize the conclusions about the effectiveness of telehealth reported in the systematic reviews involved more interpretation and decision rules. First we reviewed the conclusion of each review. Many reviews include multiple outcomes (details are provided in Appendix E); however, the conclusions needed to be summarized. The systematic review results were coded as 0=no effect, 1=unclear, 2=possible positive effect, 3=positive effect based on an assessment of the primary outcomes, as well as all outcomes. If the results had a consistent direction of effect for the primary outcomes, the codes of 0=no effect, or 3=positive effect were used. If the primary results were mixed, any secondary results were also considered. If the results had an inconsistent direction of effect and the review authors stated that a conclusion was not possible it was coded as 1=unclear in order to indicate that it was unclear what the conclusion about telehealth should be, not that the evidence was unclear. If either some primary outcomes or the majority of all outcomes showed a positive effect, the conclusion was coded as 2=possible positive effect. These codes were assigned by one team member and were checked by another team member. Any differences were discussed by the entire team and a code was assigned based on that discussion.

The weighted estimate of reported effect used in the bubble plots was created by multiplying the overall conclusion code (0 to 3) by the number of studies in the review, and then averaging the scores for all reviews in given clinical area or function. While this did not create a value with absolute meaning, it allowed us to compare the relative strength of the conclusions by clinical area or function. Based on this, the farther to the right the position of the bubble is on the plot, the more the conclusions of the reviews are consistently positive, where farther to the left indicates no effect or unclear findings.

While bubble plots and the intersection figure provide an overall picture of the literature, they can only represent limited numbers of variables and estimates that are not extremely precise (more detail is provided in the Discussion section of this brief). For this reason, we have included other tables, charts, and narratives. We used Chi-square tests to explore relationships between the conclusions of the systematic reviews and the patient setting, type of outcome, whether the reviews used quantitative analysis, and whether the reviews incorporated as assessment of the strength of evidence in their conclusions. We consider the evidence map to consist of the sum of the information in this report.