# Key Informants

In designing the study questions, the EPC consulted several Key Informants with diverse experiences and perspectives in implementing and evaluating telehealth. The EPC sought the Key Informant input to identify areas where telehealth is being used but has not been studied, issues raised by telehealth, the important questions about telehealth that different stakeholders want research evidence to answer, and to help identify the next steps in research that would be most likely to move the field forward. Key Informants were not involved in the analysis of the evidence or the writing of the report. Therefore, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Rashid L. Bashshur, Ph.D.^*^
  * Thank you to these Key Informants for their review of the draft technical brief.
  University of Michigan
  Ann Arbor, MI
- Johnathan Linkous, M.P.A.
  American Telemedicine Association
  Washington, DC
- Alan Morgan, M.P.A.
  National Rural Health Association
  Leawood, KS
- Jamie Pina, Ph.D., M.S.P.H *
  Director, Public Health Informatics Program
  RTI International
  Research Triangle Park, NC
- Karen Rheuban, M.D.^*^
  University of Virginia Center for Telehealth
  University of Virginia Telehealth System
  Charlottesville, VA
- Mark R. Thomas, P.R., M.P.H.
  Office for the Advancement of Telehealth
  U.S. Department of Health and Human Services
  Washington, DC