# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Andrew Hamilton, M.S., for literature searches; Leah Williams, B.S., for editorial support; Christine Morelli, student worker; and Elaine Graham, M.L.S., for her support and guidance in developing this report.