# Discussion

## Summary and Implications

This technical brief was designed to characterize the existing systematic reviews available to inform decisions about telehealth, using an evidence map approach. Various stakeholders, including federal and state policymakers, health care provider organizations, insurers and payers, are faced with making decisions related to supporting, implementing, and paying for telehealth. The literature, specifically in the form of systematic reviews is helpful and important to the extent that research can be used as evidence to support these decisions. When the evidence either does not exist or exists in a form that is not useful, additional work is required. An evidence map is a preliminary step in a multi-step process that can be used to identify relevant evidence and to initiate the process of developing a research agenda that can address remaining gaps.

This broad overview focuses on 58 systematic reviews that evaluate studies of telehealth, defined as the use of technology in interactions, over time or space, between providers and patients or between two providers. We grouped these results by clinical focus areas (a hybrid of conditions, body systems, and type of health care), and developed an approach to assessing the volume of the literature in terms of number of unique studies and the number of patients in these studies. We also weighted the conclusion (i.e., whether the systematic review concluded that telehealth provided a benefit) in order to provide a relative estimate of the benefit across clinical areas.

Creating bubble and intersection plots allowed us to identify areas where significant evidence exists supporting the benefits of telehealth (e.g., chronic conditions, diabetes, cardiovascular disease and behavioral health), where the evidence is more moderate (e.g., physical rehabilitation), and areas with a smaller evidence base and less positive conclusions (e.g., ICU, surgery support, and preterm birth).

We categorized abstracts of reviews in progress, reviews that mixed different interventions or did not consider the quality of the included studies, and conducted searches for primary studies in order to determine if more evidence was available for either the identified clinical focus areas with few included reviews or for areas that telehealth is likely being used or considered that were not covered by the included reviews. We identified protocols for 82 reviews in progress that would likely both increase the evidence for clinical areas we identified and add to additional topics such as maternal health and pediatrics. We also considered the reviews we excluded as indicators of the existence of primary studies that could be reanalyzed. Clinical areas not covered by our included reviews but included in reviews in process or excluded reviews were cancer, chronic pain, autism, and pregnancy.

Based on a combination of these assessments including the first bubble plot, we identified three areas where telehealth is likely being studied that were no covered by our included reviews and we conducted a search and scan of research primary literature. We identified primary studies in maternal health, in complex pediatrics, and in triage that evaluated the effectiveness of telehealth.

In a second plot, we replicated the bubble plot and organized the reviews by the health care function for which telehealth was used. In this analysis the largest number of studies and largest number of patient participants involved telehealth for communication and counseling followed by remote patient monitoring and multiple functions. A smaller evidence base of fewer studies and patients was available for the use of telehealth in psychotherapy and consultation.

Our third plot depicts the evidence at the intersection of clinical focus and function, creating smaller subgroups that we refer to as topics. This plot (Figure 10) showed that the systematic reviews that met the inclusion criteria were concentrated in communication/counseling and monitoring/management functions across all clinical categories. Cardiovascular disease/remote patient monitoring had the most evidence followed by psychotherapy and behavioral health.

We described the interventions and results in the reviews about telehealth for diabetes and communication in the results section as an example and we looked more broadly at applications for chronic diseases and telehealth use for remote patient monitoring. We also examined the impact of telehealth on service utilization and costs. Next we drew on our assessment of included and excluded reviews and our primary literature searches as well as the lack of results in some areas to develop recommendations related to the next steps in developing a research agenda and evidence base for telehealth.

Considering all the plots and additional analysis, we have created three categories for our overall assessment. These are defined as follows:

Category A: Topics that have a body of evidence in the form of several systematic reviews that according to our assessment can be used to inform decisions. For these topics there is a sizable quantity of evidence and some consistency in the conclusions. While there is always more to be learned and this research may not answer every specific question, for these topics it seems unlikely that in the near future new studies would overturn the conclusions supporting the effectiveness of telehealth.

Category B: Topics that would benefit from new or additional systematic reviews. For these topics, there appears to be enough primary studies to constitute a body of evidence, based on our assessment of excluded reviews, reviews in progress, and primary studies. However, these primary studies have not been a) synthesized in systematic reviews to date, but were identified in exploratory searches of primary literature; b) were included in reviews that did not meet the inclusion criteria (e.g. mixed interventions without separating results or did not consider the quality of the included studied); or c) were included in reviews that were unable to draw conclusions.

Category C: Topics with few primary studies completed to date and are less likely to constitute a body of evidence that could support policy decisions. Systematic reviews in these areas would risk being small and inconclusive until more primary research is done. Because this category is defined by a lack of identified evidence or evidence that is very disparate it is possible that the searches were not comprehensive or that research is constrained in these areas for good reasons. Topics in this category need to be assessed in term of importance to the field and potential reasons for the difficulty in locating or conducting primary studies (e.g., methodological or practical barriers to study).

In Table 8 below we sorted several topics into the three categories described above and provided a brief rationale for the placement in the assigned category.

Table 8 Telehealth topics: Evidence categories

Category | Topic | Rationale
A | Remote patient monitoring for chronic conditions | Several systematic reviews available, consistent findings of benefit or potential benefit from most reviews
A | Communication and counseling for chronic conditions | Several systematic reviews available, consistent findings of benefit or potential benefit from most reviews.
A | Psychotherapy for behavioral health | Most systematic reviews report benefit or potential benefit; 1 review finds insufficient evidence for use in forensic and correctional psychiatry.
B | Consultation for various clinical reasons | Four reviews addressed telehealth for consultation; three of these did not come to a conclusion. The use of telehealth for consultation crosses clinical areas and may be a viable topic for future synthesis.
B | Applications of telehealth for acute/ICU care including remote patient monitoring and telementoring | The reviews identified for ICU/surgery and burn care combined with reviews in progress in critical care and postoperative care suggest a growing literature base on this important use of telehealth designed to expand access to high tech care in areas where access is limited.
B | Maternal and child health | Pregnancy and newborn routine health care monitoring is a frequent reason for health care visits and access can be limited in some areas. A preliminary search identified studies that cover multiple technologies and uses. A future systemative review may be able to organize the literature in a way that it would be useful for policy and decisionmaking.
C | Triage for urgent and primary care | While this has been proposed as a use for telehealth, most of the identified research was on telephone only interventions. It is unclear if telehealth is not used extensively for this purpose or if it has been used but has not been studied.
C | Applications in pediatrics (managing chronic serious conditions) | Healthcare for children with serious illnesses can be disruptive and impinge on normal life, activities and development. A small number of studies were identified across diverse conditions.
C | Applications relevant to the integration of mental and physical health | Although the integration of mental and physical health is an important goal in many health care reform efforts we did not identify overlap of these topics in telehealth research (e.g., telehealth to address depression in people with diabetes or to help patients struggling with addition to obtain preventive care).
C | Impact of teledermatology on patient outcomes | While there is substantial evidence related to diagnostic concordance, we were unable to identify more than a few studies that included clinical outcomes. While diagnostic concordance is important, research focused on outcomes appears to be needed to inform decisions about this use of the telehealth.
C | Impact on cost and utilization | The evidence on costs is limited and does not correspond to the importance of this issue. Additionally, studies are needed that evaluate telehealth under new payment models.

ICU=intensive care unit

## Limitations of Evidence Maps

Evidence maps are exercises in abstraction and require a reductionist approach to information. Their purpose is to provide a view that combines a few selected variables in a way that increases understanding, but does not provide comprehensive review of the topic. Maps of a geographic area usually provide more information on a selected type of variable, such as natural features (e.g., rivers, mountains, or elevation) or manmade variables (e.g., roads, city, county, or state boundaries). Similarly, evidence maps must focus on a limited number of characteristics. These characteristics then have to be standardized and simplified in a way that allows them to be presented simultaneously. By definition, detail is reduced. Ideally the ability to identify patterns and relationships is worth the amount of detail lost and helps focus attention on which details should be re-examined using a different methodology. However, which characteristics are chosen and how data are simplified can also potentially mislead or at least not respond to the questions the analyses are designed to answer. Other than clarifying the purpose, soliciting feedback, and refining the approach, there is no way to avoid this limitation. There is no such thing as a “correct” or “definitive” evidence map. The best that can be achieved is that a map serves a useful purpose.

Additionally, like a road map, these plots provide information on key variables that help plan a route, but they do not select the route for the user. Interpretations of where the evidence is adequate and where more is needed that can vary based on perspectives and priorities of the user. Stakeholders interested in different aspects of telehealth maybe more interested in some specific uses over others. While one map cannot address all possible goals and priorities, the plots and the data in this report and the appendixes are provided in order to facilitate other considerations and interpretations.

## Limitations of the Literature

The key limitations of the literature are related to both the nature of telehealth and the current state of systematic reviews.

Telehealth is a term that has been broadly applied to a range of applications of technology in health and health care. Using one term to describe everything from generic reminders sent to a cell phone, to the use of video for psychotherapy, to a complex system that allows a physician in another location to participate in a robotic surgery remotely is problematic for many reasons. As we found, the inclusiveness of the term telehealth can make searching literature and identifying relevant studies challenging and time consuming. Perhaps more importantly, such broad application of the term increases the chance that a synthesis could make comparisons of or summaries across, very different interventions that perhaps should not be combined or compared.

Knowing the diversity that exists under the label “telehealth,” when assessing evidence we want details that help create meaningful subgroups or identify trends. However, as is often the case with complex interventions, details about the actual intervention and its implementation are often under described in primary research and/or not selected for reporting in systematic reviews. In the literature on telehealth several variables were often not reported (e.g., the studies we identified did not discuss the frequencies or the intensity of telehealth use) reported inconsistently (e.g., the particulars of use in different settings such as rural verses urban health systems) or ambiguous (e.g., the lack of clarity and readers left to assume whether telehealth was replacing or augmenting in-person care).

Systematic reviews should identify, describe, and synthesize individual studies so that the collective results are accessible and more useful. Another limitation is that not all reviews achieve this. Many reviews we examined did not go beyond cataloging the research and providing varying levels of descriptions. Some did not examine the quality of the included studies or discuss how the quality of studies should affect the interpretation of the findings. Others included very different interventions and did not separate the findings by type of intervention. The result is often either the lack of a conclusion or a tentative conclusion that is not at the confidence level required to support current practice or policy decisions about the use of specific telehealth interventions. While it is possible that these reviews were designed and executed for other reasons, there is a risk that not only will their use be limited, but that reviews become viewed by policymakers and decisionmakers as an academic exercise rather than useful tools.

Another challenge with systematic reviews in this literature is the uneven quality of studies within the reviews. Often, lower-quality studies are less likely to find an effect even where one exists such that the results of high-quality studies may be muted by lower-quality studies, especially when the latter are more numerous. This is particularly problematic when results cannot be analyzed by meta-analysis, where heterogeneity may be identified, when the stability of findings cannot be tested through sensitivity analysis, or when reviewers do not include strength of evidence assessments that include consideration of the quality of individual studies.

## Other Summaries of Telehealth Research

As part of our searching and triage, we looked for other efforts to summarize, describe, or analyze the evidence base for telehealth. In reviewing both the published literature as well as grey literature and related Web sites (e.g., U.S. government agency sites) we did not identify any other efforts to map the literature on telehealth despite the fact that there have been numerous systematic reviews. We have found no other efforts to summarize what is available to support decisions and to identify areas lacking evidence that parallels our mapping.

We did identify several “reviews of reviews”, that is syntheses of systematic reviews and meta-analyses. These are sometimes called umbrella reviews. We found seven of these umbrella reviews published since 2012.^104-110^ Some of these asked research questions that differed from the focus of this literature map. One addressed factors that promote or inhibit the implementation of any e-health system and included 37 papers published between 1995 and 2009 that were not only systematic reviews, but also narrative reviews and meta-ethnographies.108 Others defined telehealth differently than it has been defined in this literature map. A meta-review of the use of mobile phones and text messaging for self-management interventions for chronic conditions included 11 systematic reviews,107 but many of the interventions were unidirectional or not personalized (e.g., appointment reminders, general encouragement). Four of the reviews did not assess the quality of the included studies. Based on the four highest-quality reviews, the authors concluded that these technologies show promise, but that “more high-quality studies are needed to judge the long-term benefits.”

Other umbrella reviews focused on a particular technology or condition and can, in some cases, be compared to subsets of our map. A summary of 29 systematic reviews on digital self-management support for adults and children with asthma reported evidence of some beneficial effects on some outcomes but emphasized that the characteristics of the patient population and the interventions themselves were so poorly described, and so few studies included economic analysis, that understanding the potential reach and uptake was difficult.110 Another targeted study summarized the findings of 10 systematic reviews of telepsychiatry.104 While the emphasis for the review was on the feasibility of use in resource constrained environments (such as South Africa, the country of the authors), the studies in the reviews were conducted in United States, Canada, Europe, Australia, Japan, and Hong Kong. These researchers reported the reviews were of acceptable quality, but that common deficiencies were lack of grading the strength of evidence or linking the quality of the included studies to the conclusions. Nevertheless, this review of reviews concluded that telepsychiatry is as effective as face-to-face treatment and testing and does improve symptoms. Similarly, a meta-review of systematic reviews of remote monitoring for heart failure included 17 systematic reviews that summarized studies of implanted devices as well as telemonitoring. The authors rated seven of these as high-quality reviews, combined the results across these reviews, and concluded “that remote monitoring improves mortality and quality of life as well as reduces hospitalizations and, as a consequence, health care costs.”105 However, the authors noted that the evidence bases did not provide enough detail about how to best target remote monitoring to those most likely to benefit.

Two large reviews of reviews overlapped with many of the objectives of this literature map; however, they differed in both content and conclusions. Elbert 2014^106^ updated a 2010 review of reviews by Ekeland111 by summarizing reviews published 2009–2012. Their definition of eHealth was narrower than the definition of telehealth used for this map (i.e., excluded interventions that are not home based like tele-ICU) and they excluded studies of mental health and behavior change. They included 31 reviews; 7 concluded that eHealth is effective and/or cost effective and 13 concluded the evidence was promising, while 11 reported limited or inconsistent proof. The authors of this review concluded that while larger more rigorous studies could provide more definite proof of effectiveness, the evidence has been and continues to be promising and efforts could be better focused on evaluating the implementation of eHealth interventions that have been shown to be effective. McLean 2013 identified 80 systematic reviews of telehealth (using a definition similar to ours, but including phone only support as well) published between 1997 and November 2011 and summarized these as part of an evaluation for the National Health Service in the United Kingdom.109 They concluded “While reported improvements in surrogate clinical endpoints and hospitalizations are encouraging, the evidence overall remains equivocal.”109 The author attributed this to the failure of large trials to show benefit, the focus of research on evaluations of smaller projects that are not scaled in order to assess long term impact, failure to include patient and broader societal perspectives, and flawed economic analysis that did not consider downstream effects on the distribution of services.

While our literature map shares some objectives and conclusions with these reviews of reviews, by definition the scope, analysis and presentation are different. Our literature map scope is broader than many reviews of reviews, but the key difference is that the analysis is more descriptive and uses figures and tables to allow comparisons across subtopics within the literature on telehealth, in order to facilitate identification of topics for which the available evidence can support decisionmaking.

## Future Research

We identified groups of studies in clinical focus areas that have been included in reviews, but in ways that have made them less useful for decisionmaking. Specifically in many cases reviews have identified and grouped existing research together in ways that do correspond to current policy or practice issues. This evidence could be reanalyzed in order to support decisions. Additionally, there are pending reviews and individual studies on several topics that can add to the evidence base. In a field with such a wealth of information, the key will be to help decisionmakers identify what important questions are truly still outstanding and develop a research agenda for both systematic reviews and primary studies that will answer these questions. This evidence map provides a foundation for that effort.

Another less traditional approach would involve a different kind of “mapping.” It would involve outlining potential benefits of telehealth, mapping these to the goals and/or measures in health reform programs, such as value-based purchasing. Then, based on this, a research agenda for both primary research and systematic reviews could be developed that explicitly addresses the questions about what role telehealth can and should play in future reforms in health care.

As evidenced in this literature map, telehealth is used for a variety of functions within multiple clinical focus areas. Use and evaluation of telehealth is also affected by characteristics of the care setting and circumstances surrounding individual patients, as depicted in Figure 12. The studies that make up the existing knowledge base for telehealth typically focus on a limited number of research questions within a single context. A narrowed research focus and tightly defined research population can reduce confounders, but it also necessitates that a large number of studies must be conducted to provide insight into the complex system of care that an individual patient, or a patient population experiences.

Figure 12 Levels of context influencing telehealth use and evaluation

Figure 12 is a set of nested rectangles that depict the different levels of context that can interact and influence the use and evaluation of telehealth. The largest rectangle is farthest to the left and includes Telehealth type or modality and purpose. The next rectangle represents characteristics at the level of the Patient Population served by telehealth, including clinical focus, care goals and intensity, and outcomes and metrics; the third rectangle represents the level of the Care Setting including characteristics such as urban versus rural, care delivery and payment models, and inpatient versus outpatient settings. Finally, the rectangle furthest to the right within the larger rectangles represents the individual Patient and Informal caregiver characteristics and care goals and preferences that are likely to vary within patient populations.

The insights provided by narrowly defined research studies are analogous to looking at a landscape through a soda straw. The viewer can become overly confident, or miss key insights that would be more visible in a larger context. As the industry shifts toward value-based care and personalized care, the challenge will be for future telehealth research to evaluate the contributions of telehealth across care contexts. This includes within increasingly integrated care delivery models where telehealth may be but one of many modes of care that patient may simultaneously experience and where experience may vary across patients. A telehealth research network recently published a 12-point global research agenda for telehealth, in which they assert the need to “incorporate health care parameters across mediated and traditional modes of care for the benefit of providers, companies, policymakers, and the international research community.”25

The implementation of the triple aim, concurrent with move to value-based care, has elevated the cost of care and the patient experience to equal footing with clinical outcomes of care. This focus has implications for telehealth in that future research should help providers and health systems differentiate the value of telehealth services as an addition to traditional in-person care and the value of telehealth as a replacement for in-person care. Increasingly, decisionmakers will need evidence-based practices and guidelines to facilitate decisions regarding when to employ telehealth services. Guidelines will need to consider the context of care as well as the impact of telehealth services on the cost, quality and experience of care.

Future telehealth research will also need to look at multiple time horizons. Telehealth benefits may be seen at the time of the initial service, or over longer periods of time. As the Center for Medicare and Medicaid Services tests new payment and service delivery models, it will be important to ensure that clinical and administrative records reflect which parts of bundled services were delivered in-person or via telehealth to support longitudinal studies of the value of telehealth services within new service delivery models.

## Conclusion

Our searches confirmed that there is a large, broad evidence base about the effectiveness of telehealth, including over 200 systematic reviews and hundreds of primary studies published since 2006. Although we found that many reviews are not structured or conducted in a way that would support current decisions related to telehealth, we did identify a substantial amount of evidence—58 systematic reviews that covered several important clinical focus areas and met our inclusion criteria. The largest volume of research reported that telehealth interventions have produced positive results when used in the clinical areas of chronic conditions and behavioral health and when telehealth is used for providing communication/counseling and monitoring/management. Considering both clinical areas and the functions of telehealth allowed us to create more specific subgroups and look at the variation and consistency within these as well.

Based on our analysis, advancing the use telehealth maybe best served by two different research agendas. First, as this evidence map has demonstrated, there is substantial evidence supporting subsets of telehealth uses, such as remote patient monitoring for chronic conditions. In these cases, the focus should shift from effectiveness studies to broader implementation efforts and studies of barriers to spread. Two distinct approaches are needed to address gaps in the evidence with future research. One approach to future research is to continue to elaborate on our findings as well as develop additional research in a variety of clinical topics and for different health care functions for telehealth. In areas where we did not find sufficient synthesized research, such as telehealth for consultation, in ICU and surgery, and in maternal and child health new systematic reviews may be able to organize primary research (some of which is new and some of which has been included in reviews in the past) into better reviews designed to address practice and policy considerations related to these issues. Additionally, there are clinical areas and roles for telehealth that do not yet have a sufficient evidence base to support important decisions and in these cases, more primary research is needed rather than more systematic reviews. We identified triage in urgent/primary care, management of serious pediatric conditions and the integration of behavioral and physical health as three potential topics for more primary research.

The agenda is based on expanding the orientation of future work to include new organizational and payment models. Going forward, research should be conducted in emerging models of care, particularly value-based models where use of telehealth may improve the ability to share risk and attain quality and related outcomes. These studies of telehealth should consider combinations of applications of telehealth and outcomes that are important in these new models and that evaluate the specific contribution telehealth can make in these contexts.

A recent comment published in the journal Nature reported on the use of evidence maps in conservation and development. The authors point out that failure to evaluate the existing evidence can result in unnecessary harm, that relative costs and benefits may be overlooked, and people assume evidence exists that does not. They propose that a “atlas” of evidence maps that are maintained and updated could transform work in their field.11 While this single map may not rise to the level of an atlas, our experience suggests that in a field with a large diffuse evidence base, maps are useful. This map confirms that there are important areas within telehealth with substantial evidence that can support broader implementation and spread. The fact that there are other areas where evidence is still minimal should not delay building on what we do know.