# Clinical Focus Areas of Excluded Reviews

Clinical Focus | Excluded Reviews (N)
Mixed | 24
Diabetes | 23
General | 20
Congestive heart failure | 18
Psychiatry/psychology | 12
Addiction | 11
Diet/weight management/obesity | 10
Chronic disease | 6
Prevention | 6
Stroke | 6
Asthma | 5
Cancer | 5
Critical care | 5
Cardiovascular disease prevention | 4
COPD | 4
Depression | 4
Hypertension | 4
Anxiety | 3
Chronic pain | 3
Depression and anxiety | 3
Dermatology | 3
Economics - general telehealth | 3
Elderly | 3
Heart disease - implantable devices | 3
Pain | 3
Rural health | 3
Autism | 2
HIV | 2
Mixed chronic conditions | 2
Rehabilitation | 2
Acute injury | 1
Audiology | 1
Behavioral health mixed | 1
Breastfeeding | 1
Cardiovascular unspecified | 1
Diagnostic testing | 1
Emergency | 1
Hospice care | 1
Inflammatory bowel | 1
Injuries | 1
Mixed behavioral health | 1
Multiple Sclerosis | 1
Neurological disorders | 1
Physical rehabilitation | 1
Plastic surgery | 1
Pregnancy | 1
Sexual health, teen | 1
Tuberculosis | 1