# Summary of PROSPERO Search for Ongoing Systematic Reviews

The search resulted in 82 protocols. The protocols were sorted by clinical focus. Counts of protocols by clinical focus are below.

Clinical Focus | Number of Protocols
Not specified | 9
Diabetes | 6
Cardiovascular disease | 4
Weight loss | 4
Cancer | 3
Chronic pain | 3
Maternal and child health | 3
Musculoskeletal disorders | 3
Physical activity | 3
PTSD | 3
Asthma | 2
Chronic diseases | 2
Health behavior | 2
Mental Health Care, general | 2
Nutrition | 2
Aging | 1
Alcohol and tobacco use | 1
Cervical cancer screening | 1
Contraception | 1
COPD | 1
Critical Care | 1
Depression, populations with chronic illness | 1
Dermatology | 1
Dietary assessment | 1
Emergency Medical Dispatch | 1
General Practice | 1
Genetics | 1
Headache | 1
Heart failure | 1
Insomnia | 1
Interventions for caregivers | 1
Knee arthroplasty | 1
Low Vision | 1
Not specified- Adverse events | 1
Pediatric special needs | 1
Postoperative care | 1
Psychological distress | 1
Rehabilitation, Brain injury | 1
Rehabilitation, athletes | 1
Rheumatic disease | 1
Sleep apnea | 1
Smoking cessation | 1
Spinal pain | 1
STIs | 1
Stress | 1
Stroke | 1