# Individual Studies Included in the Systematic Reviews

Author | Year | Patients, N | Randomized Controlled Trial (Yes/No)
Ades | 2000 | 133 | No
Alessi | 2003 | 1 | No
Armstrong | 2007 | 451 | No
Arsand | 2008 | 9 | No
Attwood (study 1) | 2012 | 13 | No
Attwood (study 2) | 2012 | 12 | No
Baer | 1995 | 26 | No
Barnett | 2006 | 800 | No
Barth | 2001 | 32 | No
Bella | 2009 | 60 | No
Benhamou | 2007 | 60 | No
Bergmo | 1997 | Undetermined | No
Bergmo | 2000 | 375 | No
Bishai | 2003 | Undetermined | No
Bishop | 2002 | 24 | No
Bohnenkamp | 2004 | Undetermined | No
Bondmass | 1999 | 60 | No
Bose | 2001 | 13 | No
Bouchard | 2000 | 8 | No
Bouchard | 2004 | 21 | No
Bradford | 2004 | 126 | No
Breslow | 2004 | Undetermined | No
Brodey | 2000 | 43 | No
Brown | 1999 | 83 | No
Bruderman and Abboud | 1997 | 39 | No
Bruschi | 2005 | 8 | No
Bujnowska-Fedak | 2006 | 60 | No
Burgiss | 1997 | 87 | No
Byrne | 2000 | 34 | No
Carroll | 2007 | 10 | No
Chan | 2000 | Undetermined | No
Chumber | 2004 | 226 | No
Chumbler | 2005 | 537 | No
Clark | 2013 | 24 | No
Cluver | 2005 | 10 | No
Cordisco | 1999 | 81 | No
Cowain | 2000 | 1 | No
Cross | 2007 | 25 | No
Crowther | 1995 | 99 | No
Cruz | 2005 | 81 | No
Cubano | 1999 | 5 | No
Cullum | 2006 | 14 | No
Curran | 2010 | 6 | No
Dale | 2003 | 55 | No
Dalleck | 2011 | 226 | No
Dang | 2006 | 59 | No
Dang | 2007 | 41 | No
Deitsch | 2000 | 4 | No
DeMaio | 2001 | Undetermined | No
Deodhar | 2002 | Undetermined | No
Dickson | 2008 | 12 | No
Dimmick | 2003 | 34 | No
Dongier | 1986 | 50 | No
Dowie | 2007 | Undetermined | No
Duchesne | 2008 | Undetermined | No
Ehlers | 2008 | Undetermined | No
Elford | 2000 | 23 | No
Elford | 2001 | 90 | No
Elkjaer | 2010 | 21 | No
Elliot | 2007 | 36 | No
Eriksson | 2009 | 22 | No
Eron | 2006 | Undetermined | No
Farzanfar | 2004 | 5 | No
Ferrandiz | 2007 | 226 | No
Ferrer-Roca | 2004 | 23 | No
Finkelstein | 1993 | 18 | No
Finkelstein | 1996 | 41 | No
Finkelstein | 1999 | 45 | No
Finkelstein | 2000 | 31 | No
Franklin | 2008 | 64 | No
Franzini | 2011 | Undetermined | No
Frenn | 2005 | 132 | No
Frueh | 2004 | Undetermined | No
Frueh | 2005 | 18 | No
Gallar | 2007 | 57 | No
Gammon | 2005 | 30 | No
Giallauria | 2006 | 45 | No
Gilkey | 2009 | 23 | No
Granlund | 2003 | 29 | No
Grealish | 2005 | 5 | No
Greenwood | 2004 | 31 | No
Griffiths | 2006 | 15 | No
Guilfoyle | 2003 | 12 | No
Halpert | 2010 | 156 | No
Hassall | 2003 | 12 | No
Hauber | 2002 | 9 | No
Heidenreich | 1999 | 154 | No
Himle | 2005 | 3 | No
Himle | 2006 | 3 | No
Hoenig | 2006 | 13 | No
Hommel | 2013 | 9 | No
Hotta | 2007 | 101 | No
Houtchens | 1993 | 209 | No
Hsiao | 2008 | 149 | No
Hui | 2006 | 58 | No
Hyler | 2005 | 380 | No
Jarad | 2011 | 51 | No
Johansen | 2004 | 4 | No
Johnston | 2000 | 212 | No
Jones | 2001 | 30 | No
Karagiannis | 2006 | 21 | No
Katz and Nordwall | 2008 | 30 | No
Kaye | 1997 | Undetermined | No
Keays | 2006 | 344 | No
Kennedy | 2003 | 156 | No
Kennedy and Yellowlees | 2000 | 124 | No
Kennedy and Yellowlees | 2003 | 124 | No
Kim | 2005 | 45 | No
Kim | 2006 | 99 | No
Kim | 2006 | 33 | No
Kim | 2008 | 34 | No
Knol | 2006 | 306 | No
Kobb | 2003 | 281 | No
Kobb | 2003 | 1545 | No
Kollmann | 2007 | 10 | No
Kople | 2007 | 136 | No
Kortke | 2006 | 170 | No
Korzeniowska-Kubacka | 2011 | 92 | No
Kwon | 2004 | 185 | No
Lai | 2004 | 19 | No
Lamminen | 2000 | 25 | No
Larizza | 2006 | 68 | No
Lee | 2007 | 274 | No
Lehmann | 2006 | 20 | No
Lemaire | 2001 | 47 | No
Leonard | 2004 | 80 | No
Lexcen | 2006 | 72 | No
Liesenfeld | 2000 | 61 | No
Limido | 2006 | 368 | No
Linassi | 2005 | 15 | No
Lindgren | 1997 | 77 | No
Loane | 2000 | 96 | No
Lohr | 2007 | 3 | No
Lum | 2006 | 7 | No
Magrabi | 2005 | 5 | No
Mahendran | 2005 | 163 | No
Mahmud | 1995 | 12 | No
Maiolo | 2003 | 23 | No
Mair | 2008 | 20 | No
Marcin | 2004 | Undetermined | No
Marcin | 2005 | 223 | No
Massman | 1999 | 40 | No
Matsuura | 2000 | 17 | No
McCormick | 2010 | 31 | No
McManus | 2004 | 60 | No
McManus | 2008 | 2394 | No
Meheghini | 1998 | 184 | No
Mehra | 2000 | 113 | No
Miller | 2006 | 1 | No
Modai | 2006 | 42 | No
Modai | 2006 | 81 | No
Moreno-Ramirez | 2005 | 219 | No
Moreno-Ramirez | 2007 | 2539 | No
Moreno-Ramirez | 2009 | 4018 | No
Morgan | 2008 | 372 | No
Morland | 2004 | 20 | No
Morlion | 2002 | 22 | No
Morrison | 1987 | 69 | No
Morrison | 2010 | Undetermined | No
Myers | 2004 | 369 | No
Myers | 2006 | 115 | No
Myers | 2006 | 166 | No
Nakamura | 1999 | 32 | No
NEHI | 2010 | Undetermined | No
Nelson | 2003 | 28 | No
Nelson | 2004 | 62 | No
Neufield | 2007 | 289 | No
Nguyen | 2004 | 294 | No
Nikander | 2010 | 19 | No
Ortolani | 2007 | 121 | No
Pak | 1999 | 100 | No
Pak | 2007 | 508 | No
Palmer | 2005 | 233 | No
Pare | 2006 | 29 | No
Park | 2012 | 97 | No
Parker | 2010 | 10 | No
Pedersen | 2012 | 92 | No
Perini | 2008 | 13 | No
Persaud | 2005 | Undetermined | No
Phillips | 1999 | 35 | No
Piazza-Waggoner | 2006 | 1 | No
Piron | 2002 | 5 | No
Piron | 2004 | 5 | No
Pushparajah | 2006 | 80 | No
Quinn | 2006 | 26 | No
Rami | 2006 | 72 | No
Redlick | 2002 | 14 | No
Rendina | 1997 | Undetermined | No
Riva | 1999 | 1 | No
Robertson | 2006 | 104 | No
Rosenfeld | 2000 | Undetermined | No
Rosser | 1997 | 6 | No
Rossi | 2009 | 91 | No
Rossi | 2009 | 41 | No
Roth | 2004 | 118 | No
Roth | 2009 | 4598 | No
Rotondi | 2005 | 17 | No
Roy | 2008 | 1 | No
Rumberger | 2006 | Undetermined | No
Russell | 2004 | 31 | No
Ryan | 2005 | 91 | No
Sable | 1999 | Undetermined | No
Saffle | 2006 | 2 | No
Saffle | 2009 | 98 | No
Sagraves | 2007 | 311 | No
Sander | 2009 | 15 | No
Savin | 2006 | 21 | No
Sawyer | 2000 | 12 | No
Scalvini | 2005 | 230 | No
Scalvini | 2005 | 426 | No
Scalvini | 2006 | 230 | No
Scalvini | 2009 | 47 | No
Scerri | 1999 | 12 | No
Schlachra | 2009 | 26 | No
Schlachta | 2010 | 2 | No
Schoenberg | 2008 | 39 | No
Schofield | 2005 | 92 | No
Segajang | 2005 | 14 | No
Shah | 1998 | 27 | No
Shepherd | 2006 | 25 | No
Shore | 2004 | 50 | No
Shore | 2007 | 53 | No
Sicotte | 2003 | 6 | No
Sicotte | 2004 | Undetermined | No
Sieibert | 2008 | 23 | No
Simpson | 2001 | 10 | No
Smart | 2005 | 30 | No
Smith | 2002 | 5 | No
Smith | 2002 | Undetermined | No
Smith | 2002 | 1 | No
Smith | 2004 | 293 | No
Smith | 2007 | 1589 | No
Soopramanien | 2005 | 1 | No
Sorknæs | 2011 | 100 | No
Spence | 2008 | 2 | No
Spittaels | 2007 | 434 | No
Starling | 2003 | 136 | No
Steel | 2002 | 33 | No
Tam | 2003 | 3 | No
Taylor | 2001 | 188 | No
Thomas | 2005 | 38 | No
Tindall | 2008 | 24 | No
Tousignant | 2006 | 4 | No
Trappenburg | 2008 | 115 | No
Trappenburg | 2008 | 165 | No
Tsang | 2001 | 20 | No
Turner | 2009 | 23 | No
Urness | 2006 | 48 | No
Ushiyama | 2003 | 1 | No
Vaccaro | 2001 | 690 | No
Vahatalo | 2004 | 203 | No
Vahatalo | 2004 | 103 | No
Vesmarovich | 1999 | 8 | No
Vitacca | 2006 | 45 | No
Vontetsianos | 2005 | 18 | No
Voyles | 2003 | 63 | No
Wade | 2004 | 6 | No
Wade | 2004 | 19 | No
Wade | 2009 | 9 | No
Wade | 2011 | 9 | No
Wagner | 1999 | 7 | No
Wallace | 2007 | 1165 | No
Warrington | 2003 | 40 | No
Wasson | 2006 | 13271 | No
Weatherburn | 2007 | 6 | No
Wheeler | 2006 | 41 | No
Whitten | 2004 | 546 | No
Whitten | 2007 | 322 | No
Winett | 1999 | 180 | No
Winett | 2007 | 1071 | No
Wong | 2005 | 20 | No
Woods | 2011 | 48 | No
Woolf | 2006 | 273 | No
Wu | 2006 | 17 | No
Yager | 2001 | 3 | No
Yager | 2003 | 3 | No
Zanini | 2005 | 340 | No
Zarate | 1997 | 45 | No
Zawada | 2009 | Undetermined | No
Zaylor | 2000 | 49 | No
Zaylor | 2001 | 45 | No
Zbikowski | 2008 | 11143 | No
Zhou | 2007 | 6402 | No
Abbot | 2009 | 56 | Yes
Abroms | 2008 | 83 | Yes
Adachi | 2007 | 183 | Yes
Ahring | 1992 | 84 | Yes
Al Khatib | 2009 | 151 | Yes
Alkema | 2007 | 781 | Yes
Al-Khatib | 2010 | 151 | Yes
An | 2008 | 517 | Yes
Andersen | 2013 | 160 | Yes
Anderson | 2010 | 295 | Yes
Andersson | 2002 | 117 | Yes
Andersson | 2003 | 52 | Yes
Andersson | 2005 | 117 | Yes
Angermann | 2007 | 708 | Yes
Antonicelli | 2008 | 56 | Yes
Antypas | 2014 | 52 | Yes
Appel | 2002 | 27 | Yes
Appel | 2011 | 415 | Yes
Artinian | 2003 | 18 | Yes
Artinian | 2007 | 387 | Yes
Avdal | 2011 | 122 | Yes
Balk | 2008 | 214 | Yes
Barnason | 2009 | 232 | Yes
Barnett | 2007 | 212 | Yes
Bartholomew | 2000 | 133 | Yes
Bell | 2004 | 171 | Yes
Bell | 2011 | 433 | Yes
Benatar | 2003 | 216 | Yes
Bendixen | 2009 | 128 | Yes
Benhamou | 2007 | 30 | Yes
Bennete | 2010 | 101 | Yes
Bennett | 2011 | 145 | Yes
Bennett | 2012 | 365 | Yes
Bennett | 2013 | 194 | Yes
Berger | 2011 | 81 | Yes
Bergmo | 2009 | 73 | Yes
Bergström | 2010 | 65 | Yes
Berman | 2009 | 78 | Yes
Berry | 2011 | 660 | Yes
Bewick | 2008 | 317 | Yes
Biermann | 2000 | 48 | Yes
Biermann | 2002 | 43 | Yes
Blasco | 2012 | 203 | Yes
Blondel | 1992 | 168 | Yes
Blum | 2007 | 204 | Yes
Boaz | 2009 | 35 | Yes
Bogner | 2012 | 180 | Yes
Bond | 2006 | 62 | Yes
Bond | 2007 | 62 | Yes
Boriani | 2013 | 154 | Yes
Boter | 2004 | 486 | Yes
Bourbeau | 2003 | 191 | Yes
Bove | 2011 | 465 | Yes
Bove | 2013 | 241 | Yes
Bowles | 2011 | 218 | Yes
Bowns | 2006 | 165 | Yes
Boyes | 2006 | 80 | Yes
Boyne | 2012 | 382 | Yes
Brattberg | 2006 | 60 | Yes
Brendryen | 2008 | 396 | Yes
Brendryen | 2008 | 290 | Yes
Broekhuizen | 2012 | 340 | Yes
Bromberg | 2011 | 144 | Yes
Brown | 1999 | 343 | Yes
Buhrman | 2004 | 51 | Yes
Buhrman | 2011 | 50 | Yes
Buhrman | 2013 | 56 | Yes
Buhrman | 2013 | 61 | Yes
Buller | 2008 | 1234 | Yes
Buller | 2008 | 2077 | Yes
Bunjnowska-Fedak | 2011 | 95 | Yes
Butler | 2009 | 62 | Yes
Capomolla | 2004 | 133 | Yes
Carey | 2007 | 20 | Yes
Carlbring and Smit | 2008 | 66 | Yes
Carpenter | 2012 | 131 | Yes
Carrasco | 2008 | 143 | Yes
Casas | 2006 | 155 | Yes
Chambers | 2006 | 30 | Yes
Chan | 2003 | 10 | Yes
Chan | 2007 | 120 | Yes
Chandler | 1990 | 13 | Yes
Charpentier | 2011 | 120 | Yes
Chase | 2003 | 63 | Yes
Chau | 2012 | 53 | Yes
Chaudry | 2010 | 1653 | Yes
Chiantera | 2009 | 200 | Yes
Chiauzzi | 2005 | 265 | Yes
Chiauzzi | 2010 | 186 | Yes
Cho | 2006 | 71 | Yes
Cho | 2009 | 69 | Yes
Cho | 2011 | 64 | Yes
Chong | 2012 | 167 | Yes
Christian | 2011 | 323 | Yes
Chua | 2001 | Undetermined | Yes
Chumbler | 2012 | 44 | Yes
CHUMS | 1995 | 1165 | Yes
Claes | 2013 | 314 | Yes
Cleland | 2005 | 426 | Yes
Cook | 2007 | 419 | Yes
Corwin | 1996 | 377 | Yes
Cross | 2012 | 41 | Yes
Crossley | 2011 | 1997 | Yes
Crow | 2009 | Undetermined | Yes
Cruz | 2007 | 21 | Yes
Cussler | 2008 | 135 | Yes
Dale | 2009 | 231 | Yes
Dallolio | 2008 | 137 | Yes
Dansky | 2001 | 171 | Yes
Dansky | 2008 | 182 | Yes
Dansky | 2008 | 157 | Yes
Dansky | 2009 | 284 | Yes
Dar | 2009 | 182 | Yes
David | 2011 | 235 | Yes
Davis | 2010 | 165 | Yes
Day | 2002 | 80 | Yes
De Jongste | 2009 | 151 | Yes
De Las Cuevas | 2006 | 130 | Yes
de Lusignan | 2001 | 20 | Yes
De San Miguel | 2013 | 71 | Yes
de Toledo | 2006 | 157 | Yes
Dear | 2013 | 62 | Yes
DeBusk | 2004 | 462 | Yes
Dekkers | 2011 | 276 | Yes
Del Prato | 2012 | 241 | Yes
Dendale | 2012 | 160 | Yes
Deng | 2012 | 16 | Yes
Devi | 2014 | 74 | Yes
Devineni | 2005 | 86 | Yes
DeVito Dabbs | 2009 | 34 | Yes
DeWalt | 2006 | 123 | Yes
Di Biase | 1997 | 20 | Yes
Digenio | 2009 | 300 | Yes
Donohue | 2004 | 104 | Yes
Doumas & Hannah | 2008 | 82 | Yes
Dunton & Robertson | 2008 | 156 | Yes
Dyson | 1991 | 251 | Yes
Dyson | 1998 | 2422 | Yes
Eberl | 2006 | 23 | Yes
Egan | 2002 | 66 | Yes
Egner | 2003 | 27 | Yes
Ekman | 1998 | 158 | Yes
Elkjaer | 2010 | 303 | Yes
Ellison | 2004 | 56 | Yes
Ellison | 2007 | 270 | Yes
Eminovic | 2009 | 369 | Yes
Estabrooks | 2005 | 469 | Yes
Faridi | 2008 | 30 | Yes
Farmer | 2005 | 94 | Yes
Farrero | 2001 | 122 | Yes
Fell | 2000 | 160 | Yes
Finfgeld-Connett & Madsen | 2008 | 29 | Yes
Finkelstein | 2004 | 68 | Yes
Finkelstein | 2006 | 53 | Yes
Finkelstein | 2006 | 68 | Yes
Forducey | 2012 | 9 | Yes
Fortney | 2007 | 395 | Yes
Franklin | 2006 | 91 | Yes
Franklin | 2006 | 59 | Yes
Frederix | 2015 | 66 | Yes
Frederix | 2015 | 80 | Yes
Friedman | 1996 | 267 | Yes
Frueh | 2007 | 74 | Yes
Furber | 2010 | 222 | Yes
Galbreath | 2004 | 1069 | Yes
Gattis | 1999 | 181 | Yes
GESICA | 2005 | 1518 | Yes
Ghahari | 2010 | 95 | Yes
Giordano | 2007 | 461 | Yes
Giordano | 2009 | 460 | Yes
Glasgow | 2003 | 320 | Yes
Glasgow | 2005 | 886 | Yes
Glasgow | 2012 | 463 | Yes
Glasgow | 2012 | 234 | Yes
Goldberg | 2003 | 280 | Yes
Goodarzi | 2012 | 81 | Yes
Grant | 2008 | 244 | Yes
Gray | 2000 | 75 | Yes
Green | 2012 | 778 | Yes
Grzincich | 2010 | 60 | Yes
Guédon-Moreau | 2013 | 473 | Yes
Guendelman | 2002 | 134 | Yes
Guendelman | 2002 | 134 | Yes
Guendelman | 2004 | 134 | Yes
Hageman | 2005 | 31 | Yes
Halimi | 2008 | 379 | Yes
Hanauer | 2009 | 40 | Yes
Hansen | 2012 | 12,287 | Yes
Harno | 2006 | 175 | Yes
Harrison | 1999 | 132 | Yes
Harvey-Berino | 2002 | 690 | Yes
Harvey-Berino | 2004 | 232 | Yes
Harvey-Berino | 2010 | 481 | Yes
Hebert | 2006 | 44 | Yes
Hedborg | 2011 | 76 | Yes
Hee-Sung | 2007 | 51 | Yes
Hermen | 2008 | 81 | Yes
Hermens | 2007 | 81 | Yes
Hesser | 2012 | 99 | Yes
Hester & Delaney | 1997 | 40 | Yes
Hill | 2006 | 111 | Yes
Hill | 1990 | 299 | Yes
Hindricks | 2014 | 720 | Yes
Holbrook | 2009 | 511 | Yes
Hollandare | 2011 | 84 | Yes
Homer | 2000 | 137 | Yes
Homko | 2007 | 57 | Yes
Hopp | 2006 | 37 | Yes
Huang | 2006 | 497 | Yes
Huijgen | 2008 | Undetermined | Yes
Hunt | 2009 | 54 | Yes
Hunter | 2007 | 446 | Yes
Hurling | 2007 | 77 | Yes
Huss | 2003 | 101 | Yes
Hyman | 1998 | 123 | Yes
Iams | 1987 | 309 | Yes
Iams | 1990 | 76 | Yes
IDEATel trial | 2007 | 1665 | Yes
Inglis | 2004 | 152 | Yes
Inglis | 2006 | 297 | Yes
Istepanian | 2009 | 137 | Yes
Izquierdo | 2003 | 46 | Yes
Izquierdo | 2009 | 41 | Yes
Jacklin | 2003 | Undetermined | Yes
Jacobs | 2011 | 314 | Yes
Jan | 2007 | 196 | Yes
Jansa | 2006 | 40 | Yes
Japuntich | 2006 | 248 | Yes
Jarab | 2012 | 171 | Yes
Jerant | 2001 | 37 | Yes
Jerant | 2001 | Undetermined | Yes
Jerant | 2005 | 54 | Yes
Jódar-Sánchez | 2013 | 45 | Yes
Johnston | 2000 | 212 | Yes
Johnston | 2000 | 29 | Yes
Joseph | 2007 | 314 | Yes
Kaldo | 2008 | 51 | Yes
Kamei | 2011 | 37 | Yes
Kashem | 2008 | 48 | Yes
KcKay | 2001 | 78 | Yes
Kearney | 2009 | 112 | Yes
Kessler | 2009 | 255 | Yes
Khan | 2011 | 129 | Yes
Khanna and Kendall | 2010 | 49 | Yes
Kielblock | 2007 | 502 | Yes
Kim | 2003 | 50 | Yes
Kim | 2006 | 51 | Yes
Kim | 2007 | 60 | Yes
Kim | 2007 | 34 | Yes
Kim | 2008 | 51 | Yes
Kim | 2009 | 37 | Yes
Kim | 2010 | 100 | Yes
Kim and Kang | 2006 | 73 | Yes
Kim and Kim | 2008 | 34 | Yes
Kim CJ | 2006 | 73 | Yes
Kim HS | 2003 | 36 | Yes
Kim SI | 2008 | 34 | Yes
King | 2006 | 335 | Yes
King | 2009 | 37 | Yes
Kiselev | 2012 | 199 | Yes
Koehler | 2011 | 710 | Yes
Koff | 2009 | 40 | Yes
Krier | 2011 | 34 | Yes
Krishna | 2003 | 228 | Yes
Krum | 2009 | Undetermined | Yes
Krumholz | 2002 | 88 | Yes
Kulick | 2013 | 61 | Yes
Kumar | 2004 | 40 | Yes
Kunkler | 2007 | Undetermined | Yes
Kwok | 2004 | 67 | Yes
Kwon | 2004 | 80 | Yes
Kypri | 2004 | 104 | Yes
Kypri | 2008 | 576 | Yes
Kypri | 2008 | 247 | Yes
Kypri & McAnally | 2005 | 218 | Yes
Ladyzynski | 2007 | 30 | Yes
LaFramboise | 2003 | 90 | Yes
Landau | 2012 | 70 | Yes
Landolina | 2012 | 200 | Yes
Lange | 2001 | 25 | Yes
Lapp | 2012 | 46 | Yes
Laramee | 2003 | 287 | Yes
Lawrence | 2003 | 513 | Yes
Lear | 2014 | 66 | Yes
Leibreich | 2009 | 49 | Yes
Leveille | 2009 | 141 | Yes
Lewis | 2007 | 142 | Yes
Lewis | 2008 | 22 | Yes
Lewis | 2010 | 40 | Yes
Lewis & Neighbors | 2007 | 53 | Yes
Lim | 2011 | 103 | Yes
Lin | 2005 | 606 | Yes
Lindsay | 2009 | 108 | Yes
Liu | 2005 | 274 | Yes
Ljótsson | 2010 | 85 | Yes
Ljótsson | 2011 | 61 | Yes
Ljótsson | 2011 | 75 | Yes
Ljótsson | 2011 | 195 | Yes
Loane | 2000 | Undetermined | Yes
Loane | 2001 | 274 | Yes
Loane | 2001 | 203 | Yes
Loane | 2001 | Undetermined | Yes
Loane | 2001 | Undetermined | Yes
Lombard | 2010 | 250 | Yes
Lorig | 2002 | 580 | Yes
Lorig | 2006 | 958 | Yes
Lorig | 2008 | 641 | Yes
Lorig | 2008 | 855 | Yes
Lorig | 2010 | 761 | Yes
Luley | 2011 | 70 | Yes
Lusignan | 2001 | 20 | Yes
Lyneham | 2006 | 100 | Yes
Lyons | 1990 | 62 | Yes
Mabo | 2012 | 1501 | Yes
Maddison | 2014 | 139 | Yes
Madigan | 2013 | 99 | Yes
Madsen | 2008 | 236 | Yes
Mair | 2005 | 36 | Yes
Maljanian | 2005 | 336 | Yes
Man | 2006 | 109 | Yes
Mangunkusumo | 2007 | 495 | Yes
March | 2009 | 73 | Yes
Marcus | 2007 | 249 | Yes
Marrero | 1995 | 106 | Yes
Mashima | 2003 | 72 | Yes
Mayo | 2008 | 157 | Yes
McCarrier | 2009 | 77 | Yes
McConnon | 2007 | 221 | Yes
McCrossan | 2012 | 59 | Yes
McKay | 2001 | 78 | Yes
McKay | 2002 | 66 | Yes
McKay | 2008 | 2318 | Yes
McMahon | 2005 | 104 | Yes
Meer | 2009 | 200 | Yes
Meigs | 2003 | 598 | Yes
Mermelstein and Turner | 2006 | 351 | Yes
Meyer | 2008 | 222 | Yes
Mitchell | 2008 | 128 | Yes
Moattari | 2013 | 48 | Yes
Mobley | 2006 | 172 | Yes
Moore | 2005 | 100 | Yes
Moore | 2007 | 25 | Yes
Moreno | 2009 | 2169 | Yes
Morgan | 2009 | 65 | Yes
Morland | 2010 | 125 | Yes
Mortara | 2009 | 461 | Yes
Mullan | 2003 | 119 | Yes
Mulvaney | 2010 | 52 | Yes
Nagey | 1993 | 59 | Yes
Napolitano | 2003 | 65 | Yes
Neighbors | 2004 | 252 | Yes
Neighbors | 2006 | 185 | Yes
Neighbors | 2009 | 282 | Yes
Nguyen | 2008 | 51 | Yes
Nguyen | 2009 | 17 | Yes
Nguyen | 2013 | 124 | Yes
Noble | 2005 | Undetermined | Yes
Noel | 2004 | 104 | Yes
Noh | 2010 | 40 | Yes
Nolan | 2011 | 680 | Yes
Nolan | 2012 | 387 | Yes
Norman | 2008 | 1402 | Yes
O'Neill | 2008 | 58 | Yes
O'Reilly | 2007 | Undetermined | Yes
Oakley | 2000 | 203 | Yes
Oenema | 2008 | 2159 | Yes
Oenema | 2008 | 547 | Yes
Oenema | 2005 | 782 | Yes
Oerlemans | 2011 | 76 | Yes
Ohinmaa | 2002 | Undetermined | Yes
O'Reilly | 2007 | 495 | Yes
Ostojic | 2005 | 16 | Yes
Pak | 2009 | 698 | Yes
Parati | 2009 | 329 | Yes
Paschall & Bersamin | 2006 | 370 | Yes
Patrick | 2008 | 65 | Yes
Patten | 2006 | 140 | Yes
Pearson | 2006 | 762 | Yes
Pedone | 2013 | 99 | Yes
Perini | 2009 | 45 | Yes
Perl | 2013 | 151 | Yes
Phillips | 2001 | 111 | Yes
Piette | 2000 | 280 | Yes
Piette | 2001 | 272 | Yes
Piron | 2008 | 10 | Yes
Piron | 2009 | 36 | Yes
Polzien | 2007 | 28 | Yes
Poon | 2005 | 22 | Yes
Porto | 1987 | 136 | Yes
Prabhakaran | 2010 | 120 | Yes
Pressman | 2014 | 198 | Yes
Pronovost | 2009 | Undetermined | Yes
Quinn | 2008 | 30 | Yes
Quinn | 2011 | 163 | Yes
Ralston | 2009 | 83 | Yes
Ralston | 2009 | 74 | Yes
Ramachandran | 2007 | 50 | Yes
Rami | 2006 | 36 | Yes
Rasmussen | 2005 | 200 | Yes
Rasmussen | 2005 | 258 | Yes
Rasmussen | 2005 | 300 | Yes
Rea | 2004 | 135 | Yes
Reid | 2012 | 188 | Yes
Richardson | 2007 | 35 | Yes
Richardson | 2010 | 324 | Yes
Riegel | 2006 | 134 | Yes
Riegel | 2008 | 135 | Yes
Riper | 2008 | 261 | Yes
Ritterband | 2003 | 24 | Yes
Robinson | 2007 | 154 | Yes
Rodriguez-Idigoras | 2009 | 328 | Yes
Rogers | 2001 | 121 | Yes
Rogers | 2002 | 74 | Yes
Ross | 2004 | 81 | Yes
Ross | 2004 | 107 | Yes
Rossi | 2010 | 119 | Yes
Rossi | 2010 | 130 | Yes
Rothert | 2006 | 2862 | Yes
Ruehlman | 2012 | 241 | Yes
Ruffin | 2011 | 3382 | Yes
Ruland | 2003 | 52 | Yes
Ruland | 2010 | 145 | Yes
Ruskin | 2004 | 119 | Yes
Ruskin | 2004 | Undetermined | Yes
Russell | 2003 | 21 | Yes
Ruwaard | 2009 | 45 | Yes
Sainsbury | 2013 | 189 | Yes
Salazar | 2000 | 119 | Yes
Sanford | 2004 | 22 | Yes
Sanford | 2006 | 49 | Yes
Sanford | 2006 | 65 | Yes
Santamore | 2007 | 321 | Yes
Schechter | 2012 | 526 | Yes
Scherr | 2009 | 120 | Yes
Schinke | 2004 | 327 | Yes
Schneider | 1990 | 579 | Yes
Schwarz | 2008 | 102 | Yes
Scioscia | 1988 | 72 | Yes
Senesael | 2013 | 57 | Yes
Seto | 2012 | 100 | Yes
Severson | 2008 | 2523 | Yes
Shany | 2010 | 40 | Yes
Shea | 2006 | 1417 | Yes
Shea | 2006 | 1665 | Yes
Shea | 2009 | 1665 | Yes
Shetty | 2011 | 144 | Yes
Sisk | 2006 | 406 | Yes
Slootmaker | 2009 | 102 | Yes
Slootmaker | 2010 | 87 | Yes
Smith | 2012 | 32 | Yes
Sone | 2010 | 2033 | Yes
Soran | 2008 | 315 | Yes
Soran | 2008 | 345 | Yes
Southard | 2003 | 78 | Yes
Southard | 2003 | 100 | Yes
Spaeder | 2006 | 49 | Yes
Sparks | 1993 | 20 | Yes
Spence | 2006 | 72 | Yes
Spittaels | 2007 | 526 | Yes
Stallard | 2011 | 20 | Yes
Stevens | 2008 | 878 | Yes
Stone | 2010 | 150 | Yes
Strecher | 2005 | 3971 | Yes
Strom | 2000 | 45 | Yes
Svetkey | 2008 | 1032 | Yes
Swartz | 2006 | 351 | Yes
Tanaka | 2010 | 51 | Yes
Tang | 2013 | 415 | Yes
Tasker | 2007 | 37 | Yes
Tate | 2006 | 192 | Yes
Taylor | 2006 | 160 | Yes
Te Poel | 2009 | 615 | Yes
Theissing | 2013 | 164 | Yes
Thompson | 1999 | 46 | Yes
Thompson | 2009 | 138 | Yes
Thompson | 2010 | 40 | Yes
Tildesley | 2010 | 47 | Yes
Titov | 2010 | 141 | Yes
Tjam | 2006 | 57 | Yes
Tsuyuki | 2004 | 176 | Yes
Tuil | 2007 | 180 | Yes
Ueki | 2009 | 29 | Yes
van Bastelaar | 2011 | 410 | Yes
van den Berg | 2006 | 160 | Yes
van der Meer | 2009 | 200 | Yes
Van der Meer | 2010 | 200 | Yes
Van Egmond-Fröhlich | 2006 | 521 | Yes
van Wier | 2009 | 924 | Yes
Varma | 2010 | 1339 | Yes
Varnfield | 2014 | 82 | Yes
Velikova | 2004 | 216 | Yes
Verheijde | 2004 | 146 | Yes
Verheijden | 2004 | 146 | Yes
Vernmark | 2010 | 88 | Yes
Vernooij | 2012 | 246 | Yes
Villani | 2007 | 60 | Yes
Vitacca | 2009 | 101 | Yes
Wade | 2006 | 44 | Yes
Wade | 2010 | 35 | Yes
Wade | 2011 | 2200 | Yes
Wade | 2011 | 120 | Yes
Wade | 2008 and 2009 | 9 | Yes
Wagner | 2006 | 55 | Yes
Wakefield | 2008 | 148 | Yes
Wakefield | 2008 | 101 | Yes
Wakefield | 2011 | 302 | Yes
Waldman | 2008 | 1541 | Yes
Waldmann | 2008 | 1500 | Yes
Wallace | 2002 | 2094 | Yes
Walters | 2007 | 106 | Yes
Walters | 2009 | 136 | Yes
Wangberg | 2006 | 11 | Yes
Wapner | 1995 | 218 | Yes
Warren | 2000 | 28 | Yes
Weinert | 2008 | 176 | Yes
Weinert | 2011 | 209 | Yes
Weintraub | 2005 | 188 | Yes
Weintraub | 2010 | 188 | Yes
Weitzel | 2007 | 39 | Yes
Whited | 2002 | 275 | Yes
Whited | 2003 | 275 | Yes
Whitlock | 2000 | 28 | Yes
Whitten | 2007 | 83 | Yes
Wilkinson | 2008 | 7 | Yes
Willems | 2007 | 110 | Yes
Willems | 2008 | 109 | Yes
Williams | 2010 | 106 | Yes
Williamson | 2006 | 37 | Yes
Wing | 2006 | 104 | Yes
Wister | 2007 | 611 | Yes
Wojcicki | 2001 | 32 | Yes
Wolf | 2004 | 147 | Yes
Womble | 2004 | 47 | Yes
Wong | 2005 | 60 | Yes
Wong | 2005 | 120 | Yes
Wong | 2005 | 101 | Yes
Wong | 2006 | 475 | Yes
Wong | 2013 | 105 | Yes
Woodend | 2008 | 121 | Yes
Woodend | 2008 | 249 | Yes
Woodend | 2008 | 249 | Yes
Woodruff | 2007 | 136 | Yes
Wooten | 2000 | 204 | Yes
Wright | 2005 | 45 | Yes
Wylie-Rosett | 2001 | 474 | Yes
Yardley | 2010 | 714 | Yes
Yoo | 2009 | 111 | Yes
Yoo | 2009 | 111 | Yes
Yoon | 2008 | 51 | Yes
Yoon | 2008 | 51 | Yes
Yoon an Kim | 2008 | 51 | Yes
Zolfaghari | 2011 | 80 | Yes
Zugck | 2005 | Undetermined | Yes
Zutz | 2007 | 15 | Yes