# Data Abstraction of Telehealth Systematic Reviews

Author | Publication Date | Date of Searches | Purpose of Systematic Review | Setting | Type of Outcomes Reported | Systematic Review Conclusions | Systematic Review Conclusions Reached (some conclusion or unclear) | Strength of Evidence Reported in Systematic Review | Meta Analysis
Ammenwerth | 2012 | 1990 - 2011 | To systematically review the available evidence on the impact of electronic patient portals on patient care by analyzing controlled studies on the use of the use of patient portals. | Home | Clinical; Resources/Cost | Unclear | Unclear | No | No
Antonacci | 2008 | 1950 - June, 2007 | Review empirical evidence on the use and effectiveness of videoconferencing in providing diagnostic and treatment services in the area of mental health. | Home | Clinical | No Benefit | Some Conclusion | No | No
Antoniou | 2012 | 1980-April, 2011 | Evaluate efficiency and safety of telementoring in the field of general surgery. | Hospital | Clinical | Positive Benefit | Some Conclusion | Yes | No
Chaudhry | 2007 | 1966-August, 2006 | Method, efficacy, and costs of telemonitoring for CHF. | Home | Resources/Cost | No Benefit | Some Conclusion | No | No
Clark | 2015 | 1999-2011 | Compare different modalities for cardiac rehabilitation (we're pulling some, but not all sub-analyses from this report). | Mixed | Clinical | Potential Benefit | Some Conclusion | Yes | No
Clarke | 2011 | January 1969 - October 2009 | Assess the effectiveness of telemonitoring on primary and secondary outcomes. | Home | Clinical; Resources/Cost | Potential Benefit | Some Conclusion | No | Yes
Connelley | 2013 | January 2001-March 2013 | Effectiveness of telehealth in promoting physical exercise in patients with Type 2 diabetes. | Home | Clinical | Potential Benefit | Some Conclusion | Yes | No
Conway | 2014 | to November 2008 | To examine the effect of specific technology used for noninvasive remote monitoring of people with heart failure. | Home | Clinical; Resources/Cost | Positive Benefit | Some Conclusion | No | Yes
Cox | 2012 | 1998-January 2011 | Evaluate use of telehealth in people with cystic fibrosis. | Home | Clinical; Resources/Cost | No Benefit | Some Conclusion | No | No
Cruz | 2014 | to July 2013 | Assess effectiveness of home telemonitoring to reduce healthcare utilization and improve health-related outcomes of patients with COPD. | Home | Clinical; Resources/Cost | Potential Benefit | Some Conclusion | No | Yes
Dang | 2009 | 1966-2009 | Review of literature to examine the evidence for home telehealth remote monitoring in CHF management. | Home | Clinical; Resources/Cost | Positive Benefit | Some Conclusion | Yes | No
de Jong | 2014 | 2001-2013 | Do patients with chronic diseases use asynchronous communications and does it have an effect on health behavior, health outcomes, and patient satisfaction? | Home | Clinical; Resources/Cost | Positive Benefit | Some Conclusion | No | No
de Waure | 2012 | to January 22, 2010 | Does transmission of ECG from ambulance or home improve outcomes in acute MI? | Mixed | Clinical | Positive Benefit | Some Conclusion | Yes | Yes
Devi | 2015 | to December 2014 | Assess effectiveness of Internet-based intervention in mortality, lipid levels, health-related quality of life, cholesterol, BP, health care utilization, and medication compliance. | Mixed | Clinical; Resources/Cost | Unclear | Unclear | Yes | Yes
dos Santos | 2014 | January 2002-February 2012 | Objective: To systematically review the literature on the telehealth initiatives in telerehabilitation practices in children and adolescents from zero to 18 years old. | Home | Clinical | Potential Benefit | Some Conclusion | No | No
Eccleston | 2014 | 1950-mid/late 2013 | Do Internet-delivered psychological therapies improve pain symptoms, reduce disability, and improve depression and anxiety in adults with chronic pain? | Home | Clinical | Potential Benefit | Some Conclusion | No | Yes
Eland de Kok | 2011 | January 2000-July 2009 | Is e-health in chronically ill patients as effective as usual care regarding health outcomes, cost effectiveness? | Mixed | Clinical; Resources/Cost | Potential Benefit | Some Conclusion | Yes | No
Flodgren | 2015 | to June 2013 | To assess the effectiveness, acceptability, and costs of interactive telemonitoring as an alternative to, or in addition to, usual care (i.e., face-to-face care or telephone consultation). | Mixed | Clinical; Resources/Cost | Potential Benefit | Some Conclusion | Yes | Yes
Gaikwad | 2009 | June 2002- June 2007 | To evaluate the feasibility and benefits of home-based information and communications technology enabled interventions for chronic disease management, with emphasis on their impact on health outcomes and costs. | Mixed | Clinical; Resources/Cost | Potential Benefit | Some Conclusion | No | No
Gainsbury | 2011 | to September 2009 | To evaluate and summarize existing evidence regarding the effectiveness of Internet-therapy for the general class of addictive disorders. | Mixed | Clinical | Positive Benefit | Some Conclusion | No | No
Garcia-Lizana | 2007 | 1995–January 2005 | To review the clinical effectiveness of interventions using information and communication technologies for managing and controlling chronic diseases. | Mixed | Clinical; Resources/Cost | Potential Benefit | Some Conclusion | No | No
Hailey | 2010 | to November 2009 | To consider the evidence of benefit from use of telerehabilitation. | Home | Clinical; Resources/Cost | Potential Benefit | Some Conclusion | No | No
Holtz | 2012 | 2000 - May 2010 | To understand the most common uses and functions of mobile phones in monitoring and managing diabetes, their potential role in a clinical setting, and the current state of research in this area. | Mixed | Clinical | Unclear | Some Conclusion | No | No
Jaana | 2009 | 1966- December2007 | To present evidence on effects of home telemonitoring for respiratory conditions in relation to data quality, patient medical condition, utilization of health services, feasibility and use, and economic viability. | Home | Clinical; Resources/Cost | Potential Benefit | Some Conclusion | No | No
Johansen | 2012 | 1990 -November 2011 | To assess and summarize high-quality RCTs on electronic symptom or health information reporting. | Mixed | Clinical; Resources/Cost | Unclear | Unclear | No | No
Kairy | 2009 | to February 2007 | Identify clinical outcomes, clinical process, healthcare utilization, and costs associated with telerehabilitation for individuals with physical disabilities. | Mixed | Resources/Cost | Potential Benefit | Some Conclusion | No | No
Kamei | 2013 | to October 2011 | To determine whether telehealth is better than conventional treatment or disease management for patients with COPD. | Home | Clinical; Resources/Cost | Positive Benefit | Some Conclusion | Yes | Yes
Knowles | 2014 | Sep-13 | Assess impact of eHealth interventions in GI treatment. | Home | Resources/Cost | Positive Benefit | Some Conclusion | No | No
Kodama | 2012 | 1980 to April 2011 | Determine effects of internet component in obesity treatment. | Home | Clinical | Potential Benefit | Some Conclusion | No | Yes
Kotb | 2015 | to December 2012 | Determine the comparative impact of different tele-medicine options for individuals with heart failure. | Mixed | Clinical; Resources/Cost | Positive Benefit | Some Conclusion | Yes | Yes
Kumar | 2013 | January 1990 - July 2011 | To summarize data on costs of tele-ICU. | Hospital | Resources/Cost | Unclear | Unclear | No | No
Laver | 2013 | 1950 and 1980 to November 2012 | To determine the impact of telerehabilitation for stroke. | Home | Clinical | Unclear | Unclear | Yes | Yes
Liang | 2011 | January 1990 to February 2010 | To assess the effect of mobile phone intervention on glycemic control in diabetes self-management. | Mixed | Clinical | Positive Benefit | Some Conclusion | No | Yes
Lustria | 2013 | January 1999 to December 2009 | To compare the effects of tailored versus nontailored web- based interventions on health behaviors and explores the influence of key moderators on treatment outcomes. | Home | Clinical | Positive Benefit | Some Conclusion | No | Yes
Martin | 2011 | all through 2009 | To evaluate the effectiveness, patient level impact, patient and clinician satisfaction of networked communication interventions associated with meeting healthcare needs of adolescents and young adults with diagnosed mental health disorders. | Home | Clinical; Resources/Cost | Potential Benefit | Some Conclusion | No | No
McLean | 2011 | to January 2010 | To review the effectiveness of telehealthcare for COPD compared with usual face-to-face care. | Home | Clinical; Resources/Cost | Positive Benefit | Some Conclusion | Yes | Yes
Merriel | 2014 | to June 2013 | To assess the effectiveness of telehealth interventions in the primary prevention of cardiovascular disease in adult patients in community settings. | Home | Clinical | No Benefit | Some Conclusion | No | Yes
Moy | 2014 | to August 2013 | Assess benefit of blood glucose reporting in pregnant women. | Mixed | Clinical | No Benefit | Some Conclusion | Yes | Yes
Parthiban | 2015 | to August 2014 | Compare remote vs. in-person monitoring of Implantable Cardioverter-Defibrillators. | Home | Clinical; Resources/Cost | Positive Benefit | Some Conclusion | Yes | Yes
Peeters | 2011 | to December 2009. | Costs and financial benefits of video communication compared to usual care at home. | Home | Resources/Cost | No Benefit | Some Conclusion | No | No
Ramadas | 2011 | 2000 and June 2010 | Assess web-based behavioral interventions in management of type 2 diabetes mellitus. | Home | Clinical | Potential Benefit | Some Conclusion | No | No
Richards | 2012 | March 2001-March 2011 | Evaluate the overall effectiveness of computer-based treatments for depression and examine the impact of support on dropout rates and clinical outcomes. | Home | Clinical | Positive Benefit | Some Conclusion | Yes | No
Rietdijk | 2012 | to December 2011 | To describe the effectiveness of using telehealth programs to provide training or support to family members of people with traumatic brain injury. | Home | Clinical | Unclear | Unclear | Yes | No
Rooke | 2010 | to January 2009 | To quantify the overall effectiveness of computer-delivered interventions for alcohol and tobacco use. | Mixed | Clinical | Potential Benefit | Some Conclusion | No | Yes
Rooksby | 2015 | 1950-2013 | To assess efficacy of internet-delivered cognitive behavioral therapy for child anxiety disorder. | Home | Clinical | Potential Benefit | Some Conclusion | No | Yes
Saffari | 2014 | January 2003 - November 2013 | Assess glycemic control in patients with Type 2 diabetes. | Home | Clinical | Positive Benefit | Some Conclusion | Yes | Yes
Seto | 2008 | to November 2007 | Determine whether remote patient monitoring of patients with heart failure decreased costs. | Home | Resources/Cost | Positive Benefit | Some Conclusion | Yes | No
Steel | 2011 | to January 2009 | We have therefore conducted a systematic review, specifically relating to the use of videoconferencing for chronic and/or long-term conditions. | Mixed | Clinical | Potential Benefit | Some Conclusion | Yes | No
Tan | 2012 | to September 2011 | How does telehealth support families of newborn infants receiving intensive care effect the length of hospital stay? | Hospital | Resources/Cost | No Benefit | Some Conclusion | Yes | No
Toma | 2014 | 1946 - November 2013 | Assess online social networking interventions for DM counseling and information exchange compared to usual care. | Home | Clinical | Positive Benefit | Some Conclusion | No | Yes
Tran | 2008 | 1998-2008 | In-home management of chronic diseases issues include the improvement and maintenance of patients' QOL and health status, the avoidance of unnecessary trips to emergency departments, a reduction in hospital readmissions, and a reduction of costs. | Home | Clinical | Positive Benefit | Some Conclusion | Yes | Yes
Urquhart | 2015 | 1966-2014 | To determine whether home uterine monitoring is effective in improving the outcomes for women and their infants considered to be at high risk of preterm birth when compared with conventional or other care packages which do not include home uterine monitoring. | Home | Clinical; Resources/Cost | No Benefit | Some Conclusion | Yes | Yes
van Beugen | 2014 | to February 2012 | Determine how guided cognitive behavioral therapy compare with face-to-face cognitive behavioral therapy. Communication was largely via e-mail. | Home | Clinical | Potential Benefit | Some Conclusion | No | Yes
Wade | 2010 | to June, 2009 | What is the cost-benefit of real-time telehealth services? | Mixed | Clinical; Resources/Cost | Unclear | Unclear | Yes | No
Wallace | 2012 | 1966-2010 | Assess evidence for the use of telemedicine in acute burn care and outpatient based management | Mixed | Clinical; Resources/Cost | Unclear | Unclear | No | No
Warshaw | 2011 | 1990-2009 | KW 3 and 4 (excluding satisfaction) Determine: 3. How do clinical outcomes (clinical course, quality of life, visits avoided) of teledermatology compare with clinic dermatology for skin conditions? 4. How does the cost of teledermatology compare with clinic dermatology? | Mixed | Clinical; Resources/Cost | Unclear | Unclear | No | No
Widmer | 2015 | January 1990 - January 2014 | Assess benefit of digital health interventions on cardio dx outcomes and risk-factors, compared with non-digital-health interventions | Mixed | Clinical | Positive Benefit | Some Conclusion | No | Yes
Zhai | 2014 | 2000-February 2014. | Perform a meta-analysis of RCTs of telemedicine on HbA1c | Home | Clinical; Resources/Cost | Unclear | Unclear | Yes | Yes

Please see Appendix C. Included Studies for full study references.

BP=blood pressure, CHF=congestive heart failure, COPD=chronic obstructive pulmonary disorder, DM=diabetes mellitus, ECG=electrocardiogram, GI=gastrointestinal, ICU=intensive care unit, MI=myocardial infarction, RCT=randomized controlled trial, QOL=quality of life