# Systematic Review Characteristics, Modality, and Function

Author | Year | End Date of Search | Clinical Indication (Broad Category) | Clinical Indication (Narrow Category) | Telehealth Function | Telehealth Modality | Individual Studies (N) | Randomized Controlled Trials (N) | Randomized Controlled Trials (%) | Patients (N)
Ammenwerth | 2012 | 2011 | Mixed | Mixed | Communication and counseling | Asynchronous communication | 4 | 3 | 75.00% | 6907
Antonacci | 2008 | 2007 | Behavioral health | Mixed behavioral health | Psychotherapy | Videoconferencing | 45 | 5 | 11.11% | 3835
Antoniou | 2012 | 2011 | ICU or surgery support | Surgical telementoring | Telementoring | Videoconferencing | 10 | 0 | 0.00% | 118
Chaudhry | 2007 | 2006 | Cardiovascular disease | CHF | Remote patient monitoring | Mixed | 4 | 4 | 100.00% | 959
Clark | 2015 | 2011 | Cardiovascular disease | Cardiac rehabilitation | Telerehabilitation | Mixed | 12 | 5 | 41.67% | 1165
Clarke | 2011 | 2009 | Cardiovascular disease | CHF | Remote patient monitoring | Mixed | 13 | 13 | 100.00% | 3202
Connelley | 2013 | 2013 | Diabetes | Diabetes | Communication and counseling | Mixed | 15 | 15 | 100.00% | 4567
Conway | 2014 | 2008 | Cardiovascular disease | CHF | Remote patient monitoring | Mixed | 11 | 11 | 100.00% | 3031
Cox | 2012 | 2011 | Respiratory disease | Cystic fibrosis | Multiple functions | Mixed | 7 | 2 | 28.57% | 203
Cruz | 2014 | 2013 | Respiratory disease | COPD | Remote patient monitoring | Asynchronous communication | 9 | 7 | 77.78% | 583
Dang | 2009 | 2009 | Cardiovascular disease | CHF | Remote patient monitoring | Mixed | 9 | 9 | 100.00% | 2149
de Jong | 2014 | 2013 | Mixed chronic condition | Mixed chronic condition | Communication and counseling | Asynchronous communication | 15 | 15 | 100.00% | 2657
de Waure | 2012 | 2010 | Cardiovascular disease | Myocardial Infarction | Consultation | Mixed | 5 | 1 | 20.00% | 6927
Devi | 2015 | 2014 | Cardiovascular disease | Cardiovascular disease prevention | Multiple functions | Asynchronous communication | 11 | 11 | 100.00% | 1112
dos Santos | 2014 | 2010 | Physical rehabilitation | Pediatric physical rehabilitation | Telerehabilitation | Mixed | 9 | 9 | 100.00% | 933
Eccleston | 2014 | 2013 | Mixed chronic condition | Chronic pain | Psychotherapy | Videoconferencing | 15 | 15 | 100.00% | 2014
Eland de Kok | 2011 | 2009 | Mixed chronic condition | Mixed chronic condition | Multiple functions | Asynchronous communication | 12 | 12 | 100.00% | 2144
Flodgren | 2015 | 2013 | Mixed | Mixed | Multiple functions | Mixed | 93 | 93 | 100.00% | 22119
Gaikwad | 2009 | 2007 | Mixed chronic condition | Mixed chronic condition | Multiple functions | Mixed | 21 | 8 | 38.10% | 16962
Gainsbury | 2011 | 2009 | Behavioral health | Addictive disorder | Psychotherapy | Mixed | 9 | 7 | 77.78% | 12561
Garcia-Lizana | 2007 | 2005 | Mixed chronic condition | Mixed chronic condition | Remote patient monitoring | Mixed | 24 | 24 | 100.00% | 3764
Hailey | 2010 | 2009 | Physical rehabilitation | Physical rehabilitation | Telerehabilitation | Mixed | 27 | 21 | 77.78% | 3234
Holtz | 2012 | 2010 | Diabetes | Diabetes | Multiple functions | Mobile phone | 21 | 10 | 47.62% | 1035
Jaana | 2009 | 2007 | Respiratory disease | Mixed respiratory | Remote patient monitoring | Mixed | 23 | 8 | 34.78% | 1464
Johansen | 2012 | 2011 | Mixed | Mixed | Communication and counseling | Mixed | 29 | 29 | 100.00% | 6104
Kairy | 2009 | 2007 | Physical rehabilitation | Physical rehabilitation | Telerehabilitation | Videoconferencing | 28 | 8 | 28.57% | 1039
Kamei | 2013 | 2011 | Respiratory disease | COPD | Remote patient monitoring | Mixed | 7 | 5 | 71.43% | 590
Knowles | 2014 | 2013 | Mixed | Mixed GI | Communication and counseling | Asynchronous communication | 15 | 9 | 60.00% | 1371
Kodama | 2012 | 2011 | Mixed chronic condition | Obesity | Communication and counseling | Asynchronous communication | 23 | 23 | 100.00% | 9076
Kotb | 2015 | 2012 | Cardiovascular disease | CHF | Remote patient monitoring | Mixed | 30 | 30 | 100.00% | 11690
Kumar | 2013 | 2011 | ICU or surgery support | Tele-ICU | Consultation | Videoconferencing | 8 | 0 | 0.00% | 0
Laver | 2013 | 2012 | Physical rehabilitation | Tele-stroke | Telerehabilitation | Videoconferencing | 10 | 10 | 100.00% | 810
Liang | 2011 | 2010 | Diabetes | Diabetes | Communication and counseling | Mobile phone | 21 | 11 | 52.38% | 1604
Lustria | 2013 | 2009 | Mixed | Mixed Health Behaviors | Communication and counseling | Asynchronous communication | 39 | 33 | 84.62% | 26030
Martin | 2011 | 2009 | Behavioral health | Behavioral health | Psychotherapy | Mixed | 12 | 2 | 16.67% | 533
McLean | 2011 | 2010 | Respiratory disease | COPD | Remote patient monitoring | Asynchronous communication | 10 | 10 | 100.00% | 907
Merriel | 2014 | 2013 | Cardiovascular disease | Cardiovascular disease prevention | Communication and counseling | Asynchronous communication | 13 | 13 | 100.00% | 9500
Moy | 2014 | 2013 | Diabetes | Diabetes | Remote patient monitoring | Asynchronous communication | 2 | 2 | 100.00% | 52
Parthiban | 2015 | 2014 | Cardiovascular disease | Implantable cardioverter-defibrillators | Remote patient monitoring | Asynchronous communication | 9 | 9 | 100.00% | 6686
Peeters | 2011 | 2009 | Mixed chronic condition | Mixed chronic condition | Remote patient monitoring | Videoconferencing | 9 | 4 | 44.44% | 2663
Ramadas | 2011 | 2010 | Diabetes | Diabetes | Multiple functions | Asynchronous communication | 13 | 11 | 84.62% | 1647
Richards | 2012 | 2011 | Behavioral health | Depression | Psychotherapy | Mixed | 10 | 8 | 80.00% | 937
Rietdijk | 2012 | 2011 | Physical rehabilitation | Traumatic brain injury | Communication and counseling | Mixed | 16 | 7 | 43.75% | 1150
Rooke | 2010 | 2009 | Behavioral health | Addictive disorder | Communication and counseling | Asynchronous communication | 34 | 34 | 100.00% | 9951
Rooksby | 2015 | 2013 | Behavioral health | Anxiety | Psychotherapy | Mixed | 7 | 4 | 57.14% | 241
Saffari | 2014 | 2013 | Diabetes | Diabetes | Remote patient monitoring | Mixed | 6 | 6 | 100.00% | 657
Seto | 2008 | 2007 | Cardiovascular disease | CHF | Remote patient monitoring | Mixed | 10 | 4 | 40.00% | 1404
Steel | 2011 | 2009 | Mixed chronic condition | Mixed chronic condition | Multiple functions | Videoconferencing | 35 | 10 | 28.57% | 2659
Tan | 2012 | 2011 | ICU or surgery support | NICU family support | Communication and counseling | Videoconferencing | 1 | 1 | 100.00% | 75
Toma | 2014 | 2013 | Diabetes | Diabetes | Communication and counseling | Asynchronous communication | 34 | 34 | 100.00% | 4977
Tran | 2008 | 2008 | Mixed chronic condition | Mixed chronic condition | Remote patient monitoring | Mixed | 78 | 48 | 61.54% | 17217
Urquhart | 2015 | 2014 | Preterm birth | Preterm birth | Remote patient monitoring | Asynchronous communication | 15 | 14 | 93.33% | 6026
van Beugen | 2014 | 2012 | Behavioral health | Mixed behavioral health | Psychotherapy | Asynchronous communication | 23 | 23 | 100.00% | 4712
Wade | 2010 | 2009 | Mixed | Mixed | Multiple functions | Videoconferencing | 36 | 18 | 50.00% | 581
Wallace | 2012 | 2010 | Burn care | Burn care | Consultation | Mixed | 16 | 0 | 0.00% | 6588
Warshaw | 2011 | 2009 | Dermatological conditions | Mixed | Consultation | Mixed | 24 | 8 | 33.33% | 11942
Widmer | 2015 | 2015 | Cardiovascular disease | Cardiovascular disease prevention | Communication and counseling | Mixed | 29 | 28 | 96.55% | 18500
Zhai | 2014 | 2014 | Diabetes | Diabetes | Multiple functions | Mixed | 35 | 35 | 100.00% | 8149

Please see Appendix C. Included Studies for full study references.

CHF=congestive heart failure, COPD=chronic obstructive pulmonary disease, GI=Gastrointestinal, ICU=intensive care unit, NICU=neonatal intensive care unit.