# Excluded Reviews

Review articles were excluded if they analyzed studies with various interventions together, if they did not meet our criteria for systematic reviews, or both.

Aalbers T, Baars MAE, Rikkert MGMO. Characteristics of effective Internet-mediated interventions to change lifestyle in people aged 50 and older: a systematic review. Ageing Res Rev. 2011;10(4):487-97. [pmid: 21628005].
Aardoom JJ, Dingemans AE, Spinhoven P, et al. Treating eating disorders over the internet: a systematic review and future research directions. Int J Eat Disord. 2013;46(6):539-52. [pmid: 23674367].
Agboola SO, Ju W, Elfiky A, et al. The effect of technology-based interventions on pain, depression, and quality of life in patients with cancer: a systematic review of randomized controlled trials. J Med Internet Res. 2015;17(3):e65. [pmid: 25793945].
Aguilar-Martinez A, Sole-Sedeno JM, Mancebo-Moreno G, et al. Use of mobile phones as a tool for weight loss: a systematic review. J Telemed Telecare. 2014;20(6):339-49. [pmid: 24875928].
Almeida P, Caetano F, Carvalho A, et al. Interactive applications for patient education and behaviour change in asthma. 2006.
An J-Y, Hayman LL, Park Y-S, et al. Web-based weight management programs for children and adolescents: a systematic review of randomized controlled trial studies. ANS Adv Nurs Sci. 2009;32(3):222-40. [pmid: 19707091].
Andersson G. Guided internet treatment for anxiety disorders. As effective as face-to-face therapies?. Stud Health Technol Inform. 2012;181:3-7. [pmid: 22954817].
Andersson G, Cuijpers P. Internet-based and other computerized psychological treatments for adult depression: a meta-analysis. Cognitive Behav Ther. 2009;38(4):196-205. [pmid: 20183695].
Andrews G, Cuijpers P, Craske MG, et al. Computer therapy for the anxiety and depressive disorders is effective, acceptable and practical health care: a meta-analysis. PLoS One. 2010;5(10):e13196. [pmid: 20967242].
Aneni EC, Roberson LL, Maziak W, et al. A systematic review of internet-based worksite wellness approaches for cardiovascular disease risk management: outcomes, challenges & opportunities. PLoS ONE. 2014;9(1):e83594. [pmid: 24421894].
Angeles RN, Howard MI, Dolovich L. The Effectiveness of Web-Based Tools for Improving Blood Glucose Control in Patients with Diabetes Mellitus: A Meta-Analysis. Canadian Journal of Diabetes. 2011;35(4):344-52.
Aresti-Bartolome N, Garcia-Zapirain B. Technologies as support tools for persons with autistic spectrum disorder: a systematic review. Int J Environ Res Public Health. 2014;11(8):7767-802. [pmid: 25093654].
Atherton H, Sawmynaden P, Sheikh A, et al. Email for clinical communication between patients/caregivers and healthcare professionals. Cochrane Database Syst Rev. 2012;11. CD007978. [pmid: 23152249].
Bacigalupo R, Cudd P, Littlewood C, et al. Interventions employing mobile technology for overweight and obesity: an early systematic review of randomized controlled trials. Obes Rev. 2013;14(4):279-91. [pmid: 23167478].
Backhaus A, Agha Z, Maglione ML, et al. Videoconferencing psychotherapy: a systematic review. Psychol Serv. 2012;9(2):111-31. [pmid: 22662727].
Baron J, McBain H, Newman S. The impact of mobile monitoring technologies on glycosylated hemoglobin in diabetes: a systematic review. J Diabetes Sci Technol. 2012;6(5):1185-96. [pmid: 23063046].
Bashshur RL, Shannon GW, Smith BR, et al. The empirical foundations of telemedicine interventions for chronic disease management. Telemed J E Health. 2014;20(9):769-800. [pmid: 24968105].
Bashshur RL, Shannon GW, Smith BR, et al. The empirical evidence for the telemedicine intervention in diabetes management. Telemed J E Health. 2015;21(5):321-54. [pmid: 25806910].
Bashshur RL, Shannon GW, Tejasvi T, et al. The Empirical Foundations of Teledermatology: A Review of the Research Evidence. Telemed J E Health. 2015. [pmid: 26394022].
Bender JL, Radhakrishnan A, Diorio C, et al. Can pain be managed through the Internet? A systematic review of randomized controlled trials. Pain. 2011;152(8):1740-50. [pmid: 21565446].
Bennett GG, Steinberg DM, Stoute C, et al. Electronic health (eHealth) interventions for weight management among racial/ethnic minority adults: a systematic review. Obes Rev. Suppl 4. 2014;15:146-58. [pmid: 25196411].
Bergmo TS. Economic evaluation in telemedicine - still room for improvement. J Telemed Telecare. 2010;16(5):229-31. [pmid: 20501629].
Boisvert M, Lang R, Andrianopoulos M, et al. Telepractice in the assessment and treatment of individuals with autism spectrum disorders: A systematic review. Dev Neurorehabil. 2010;13(6):423-32. [pmid: 20887200].
Bolton CE, Waters CS, Peirce S, et al. Insufficient evidence of benefit: a systematic review of home telemonitoring for COPD. J Eval Clin Pract. 2011;17(6):1216-22. [pmid: 20846317].
Botsis T, Hartvigsen G. Current status and future perspectives in telecare for elderly people suffering from chronic diseases. J Telemed Telecare. 2008;14(4):195-203. [pmid: 18534954].
Brennan L, Castro S, Brownson RC, et al. Accelerating evidence reviews and broadening evidence standards to identify effective, promising, and emerging policy and environmental strategies for prevention of childhood obesity. Annu Rev Public Health. 2011;32:199-223. [pmid: 21219169].
Burri H, Sticherling C, Wright D, et al. Cost-consequence analysis of daily continuous remote monitoring of implantable cardiac defibrillator and resynchronization devices in the UK. Europace. 2013;15(11):1601-8. [pmid: 23599169].
Calear AL, Christensen H. Review of internet-based prevention and treatment programs for anxiety and depression in children and adolescents. Med J Aust. 2010;192(11 Suppl):S12-4. [pmid: 20528700].
Canada Health Infoway. Connecting Patients with Providers: A Pan-Canadian Study on Remote Patient Monitoring. 2014.
Carter BL, Bosworth HB, Green BB. The hypertension team: the role of the pharmacist, nurse, and teamwork in hypertension therapy. J Clin Hypertens (Greenwich). 2012;14(1):51-65. [pmid: 22235824].
Cherofsky N, Onua E, Sawo D, et al. Telehealth in adult patients with congestive heart failure in long term home health care: a systematic review. The JBI Database of Systematic Reviews and Implementation Reports. 2011;9(30):1271-96.
Ciere Y, Cartwright M, Newman SP. A systematic review of the mediating role of knowledge, self-efficacy and self-care behaviour in telehealth patients with heart failure. J Telemed Telecare. 2012;18(7):384-91. [pmid: 23019605].
Clark AM, Haykowsky M, Kryworuchko J, et al. A meta-analysis of randomized control trials of home-based secondary prevention programs for coronary artery disease. Eur J Cardiovasc Prev Rehabil. 2010;17(3):261-70. [pmid: 20560165].
Clark RA, Inglis SC, McAlister FA, et al. Telemonitoring or structured telephone support programmes for patients with chronic heart failure: systematic review and meta-analysis. Bmj. 2007;334(7600):942. [pmid: 17426062].
Costa BM, Fitzgerald KJ, Jones KM, et al. Effectiveness of IT-based diabetes management interventions: a review of the literature. BMC Fam Pract. 2009;10:72. [pmid: 19917136].
Costa PD, Rodrigues PP, Reis AH, et al. A review on remote monitoring technology applied to implantable electronic cardiovascular devices. Telemed J E Health. 2010;16(10):1042-50. [pmid: 21070132].
Cotter AP, Durant N, Agne AA, et al. Internet interventions to support lifestyle modification for diabetes management: a systematic review of the evidence. J Diabetes Complications. 2014;28(2):243-51. [pmid: 24332469].
Cucciare MA, Weingardt KR, Humphreys K. How Internet technology can improve the quality of care for substance use disorders. Curr Drug Abuse Rev. 2009;2(3):256-62. [pmid: 20443772].
Cuijpers P, van Straten A, Andersson G. Internet-administered cognitive behavior therapy for health problems: a systematic review. J Behav Med. 2008;31(2):169-77. [pmid: 18165893].
Dalal HM, Zawada A, Jolly K, et al. Home based versus centre based cardiac rehabilitation: Cochrane systematic review and meta-analysis (Erratum). 3402010. PMID.
Dalal HM, Zawada A, Jolly K, et al. Home based versus centre based cardiac rehabilitation: Cochrane systematic review and meta-analysis. Bmj. 2010;340:b5631. [pmid: 20085991].
Dalton JE. Web-based care for adults with type 2 diabetes. Can J Diet Pract Res. 2008;69(4):185-91. [pmid: 19063808].
de la Vega R, Miro J. mHealth: a strategic field without a solid scientific soul. a systematic review of pain-related apps. PLoS ONE. 2014;9(7):e101312. [pmid: 24999983].
Dedert EA, McDuffie JR, Stein R, et al. Electronic Interventions for Alcohol Misuse and Alcohol Use Disorders: A Systematic Review. Ann Intern Med. 2015;163(3):205-14. [pmid: 26237752].
Dellifraine JL, Dansky KH. Home-based telehealth: a review and meta-analysis. J Telemed Telecare. 2008;14(2):62-6. [pmid: 18348749].
Deshpande A, Khoja S, Lorca J, et al. Asynchronous telehealth: Systematic review of analytic studies and environmental scan of relevant initiatives. Canadian Agency for Drugs and Technologies in Health. Ottawa. 2008.
Donker T, Petrie K, Proudfoot J, et al. Smartphones for smarter delivery of mental health programs: a systematic review. J Med Internet Res. 2013;15(11):e247. [pmid: 24240579].
Dorstyn D, Mathias J, Denson L. Applications of telecounselling in spinal cord injury rehabilitation: a systematic review with effect sizes. Clin Rehabil. 2013;27(12):1072-83. [pmid: 23823709].
Dorstyn DS, Saniotis A, Sobhanian F. A systematic review of telecounselling and its effectiveness in managing depression amongst minority ethnic communities. J Telemed Telecare. 2013;19(6):338-46. [pmid: 24163298].
Dubner S, Auricchio A, Steinberg JS, et al. ISHNE/EHRA expert consensus on remote monitoring of cardiovascular implantable electronic devices (CIEDs). Ann Noninvasive Electrocardiol. 2012;17(1):36-56. [pmid: 22276627].
Duvvuri VR, Jianhong W. Information and communication technology developments in asthma management: a systematic review. Indian J Med Sci. 2007;61(4):221-41. [pmid: 17401261].
Edwards P, Felix L, Harris J, et al. Assessing the effectiveness and cost effectiveness of adaptive e-Learning to improve dietary behaviour: protocol for a systematic review. BMC Public Health. 2010;10:200. [pmid: 20409308].
Ekeland AG, Bowes A, Flottorp S. Methodologies for assessing telemedicine: a systematic review of reviews. Int J Med Inf. 2012;81(1):1-11. [pmid: 22104370].
Finitsis DJ, Pellowski JA, Johnson BT. Text message intervention designs to promote adherence to antiretroviral therapy (ART): a meta-analysis of randomized controlled trials. PLoS ONE. 2014;9(2):e88166. [pmid: 24505411].
Fisher E, Law E, Palermo TM, et al. Psychological therapies (remotely delivered) for the management of chronic and recurrent pain in children and adolescents. Cochrane Database Syst Rev. 2015;(3).
Fjeldsoe BS, Marshall AL, Miller YD. Behavior change interventions delivered by mobile telephone short-message service. Am J Prev Med. 2009;36(2):165-73. [pmid: 19135907].
Frade S, Rodrigues H. Benefits, challenges and impact of teleconsultation - a literature review. Stud Health Technol Inform. 2013;192:1157. [pmid: 23920931].
Franek J. Home telehealth for patients with chronic obstructive pulmonary disease (COPD): an evidence-based analysis. Ont Health Technol Assess Ser. 2012;12(11):1-58. [pmid: 23074421].
Free C, Phillips G, Galli L, et al. The effectiveness of mobile-health technology-based health behaviour change or disease management interventions for health care consumers: a systematic review. PLoS Med. 2013;10(1):e1001362. [pmid: 23349621].
Free C, Phillips G, Watson L, et al. The effectiveness of mobile-health technologies to improve health care service delivery processes: a systematic review and meta-analysis. PLoS Med. 2013;10(1):e1001363. [pmid: 23458994].
Gamble JE, Savage GT, Icenogle ML. Value-chain analysis of a rural health program: toward understanding the cost benefit of telemedicine applications. Hosp Top. 2004;82(1):10-7. [pmid: 15490956].
Garcia-Lizana F, Munoz-Mayorga I. Telemedicine for depression: a systematic review. Perspect Psychiatr Care. 2010;46(2):119-26. [pmid: 20377799].
García-Lizana F, Muñoz-Mayorga I. What about telepsychiatry? A systematic review. Primary care companion to the Journal of clinical psychiatry. 2010;12(2).
Gardiner S, Hartzell TL. Telemedicine and plastic surgery: a review of its applications, limitations and legal pitfalls. J Plast Reconstr Aesthet Surg. 2012;65(3):e47-53. [pmid: 22178033].
Geraedts H, Zijlstra A, Bulstra SK, et al. Effects of remote feedback in home-based physical activity interventions for older adults: a systematic review. Patient Educ Couns. 2013;91(1):14-24. [pmid: 23194823].
Ghanbarzadeh R, Ghapanchi AH, Blumenstein M. Application areas of multi-user virtual environments in the healthcare context. Stud Health Technol Inform. 2014;204:38-46. [pmid: 25087525].
Giamouzis G, Mastrogiannis D, Koutrakis K, et al. Telemonitoring in chronic heart failure: a systematic review. Cardiol Res Pract. 2012;2012:410820. [pmid: 22720184].
Goldzweig CL, Orshansky G, Paige NM, et al. Electronic patient portals: evidence on health outcomes, satisfaction, efficiency, and attitudes: a systematic review. Ann Intern Med. 2013;159(10):677-87. [pmid: 24247673].
Goyal S, Cafazzo JA. Mobile phone health apps for diabetes management: current evidence and future developments. Qjm. 2013;106(12):1067-9. [pmid: 24106313].
Gremeaux V, Coudeyre E. The Internet and the therapeutic education of patients: A systematic review of the literature. Ann Phys Rehabil Med. 2010;53(10):669-92. [pmid: 21036689].
Griffiths KM, Farrer L, Christensen H. The efficacy of internet interventions for depression and anxiety disorders: a review of randomised controlled trials. Med J Aust. 2010;192(11 Suppl):S4-11. [pmid: 20528707].
Guedon-Moreau L, Mabo P, Kacet S. Current clinical evidence for remote patient management. Europace. Suppl 1. 2013;15:i6-i10. [pmid: 23737234].
Guljas R, Ahmed A, Chang K, et al. Impact of telemedicine in managing type 1 diabetes among school-age children and adolescents: an integrative review. Journal of Pediatric Nursing. 2014;29(3):198-204. [pmid: 24269308].
Gurne O, Conraads V, Missault L, et al. A critical review on telemonitoring in heart failure. Acta Cardiol. 2012;67(4):439-44. [pmid: 22997998].
Gurol-Urganci I, de Jongh T, Vodopivec-Jamsek V, et al. Mobile phone messaging for communicating results of medical investigations. Cochrane Database Syst Rev. 2012;6. CD007456. [pmid: 22696369].
Guse K, Levine D, Martins S, et al. Interventions using new digital media to improve adolescent sexual health: a systematic review. J Adolesc Health. 2012;51(6):535-43. [pmid: 23174462].
Gustafson DH, Shaw BR, Isham A, et al. Explicating an evidence-based, theoretically informed, mobile technology-based system to improve outcomes for people in recovery for alcohol dependence. Subst Use Misuse. 2011;46(1):96-111. [pmid: 21190410].
Haesum LKE, Ehlers L, Hejlesen OK. Telehomecare technologies enhance self-management and empowerment among patients with chronic obstructive pulmonary disease (COPD) - where does health literacy fit into this equation?. Stud Health Technol Inform. 2013;192:1182. [pmid: 23920956].
Hailey D, Roine R, Ohinmaa A. The effectiveness of telemental health applications: a review. Can J Psychiatry. 2008;53(11):769-78. [pmid: 19087471].
Hailey D, Roine R, Ohinmaa A, et al. Evidence of benefit from telerehabilitation in routine care: a systematic review. J Telemed Telecare. 2011;17(6):281-7. [pmid: 21844172].
Hailey D, Roine R, Ohinmaa A, et al. The status of telerehabilitation in neurological applications. J Telemed Telecare. 2013;19(6):307-10. [pmid: 24163293].
Hall AK, Cole-Lewis H, Bernhardt JM. Mobile text messaging for health: a systematic review of reviews. Annual Review of Public Health. 2015;36:393-415. [pmid: 25785892].
Hall CS, Fottrell E, Wilkinson S, et al. Assessing the impact of mHealth interventions in low- and middle-income countries--what has been shown to work?. Glob Health Action. 2014;7:25606. [pmid: 25361730].
Hameed AS, Sauermann S, Schreier G. The impact of adherence on costs and effectiveness of telemedical patient management in heart failure: a systematic review. Applied Clinical Informatics. 2014;5(3):612-20. [pmid: 25298802].
Hamine S, Gerth-Guyette E, Faulx D, et al. Impact of mHealth chronic disease management on treatment adherence and patient outcomes: a systematic review. J Med Internet Res. 2015;17(2):e52. [pmid: 25803266].
Hasselberg M, Beer N, Blom L, et al. Image-based medical expert teleconsultation in acute care of injuries. A systematic review of effects on information accuracy, diagnostic validity, clinical outcome, and user satisfaction. PLoS ONE. 2014;9(6):e98539. [pmid: 24887257].
Head KJ, Noar SM, Iannarino NT, et al. Efficacy of text messaging-based interventions for health promotion: a meta-analysis. Soc Sci Med. 2013;97:41-8. [pmid: 24161087].
Hedman E, Ljotsson B, Lindefors N. Cognitive behavior therapy via the Internet: a systematic review of applications, clinical efficacy and cost-effectiveness. Expert rev. 2012;12(6):745-64. [pmid: 23252357].
Herbert L, Owen V, Pascarella L, et al. Text message interventions for children and adolescents with type 1 diabetes: a systematic review. Diabetes Technol Ther. 2013;15(5):362-70. [pmid: 23550554].
Hess DC, Audebert HJ. The history and future of telestroke. Nat Rev Neurol. 2013;9(6):340-50. [pmid: 23649102].
Huang VW, Reich KM, Fedorak RN. Distance management of inflammatory bowel disease: systematic review and meta-analysis. World J Gastroenterol. 2014;20(3):829-42. [pmid: 24574756].
Huckvale C, Car J, Akiyama M, et al. Information technology for patient safety. Qual Saf Health Care. Suppl 2. 2010;19:i25-33. [pmid: 20693213].
Hutchesson MJ, Rollo ME, Krukowski R, et al. eHealth interventions for the prevention and treatment of overweight and obesity in adults: a systematic review with meta-analysis. Obes Rev. 2015;16(5):376-92. [pmid: 25753009].
Inglis SC, Clark RA, Dierckx R, et al. Structured telephone support or non-invasive telemonitoring for patients with heart failure. Cochrane Database Syst Rev. 2015;(10). [pmid: 26517969].
Inglis SC, Clark RA, McAlister FA, et al. Structured telephone support or telemonitoring programmes for patients with chronic heart failure. Cochrane Database Syst Rev. 2010;(8). CD007228. [pmid: 20687083].
Inglis SC, Conway A, Cleland JG, et al. Is age a factor in the success or failure of remote monitoring in heart failure? Telemonitoring and structured telephone support in elderly heart failure patients. Eur J Cardiovasc Nurs. 2015;14(3):248-55. [pmid: 24681423].
Institute of Health Economics. Telehealth in substance abuse and addiction review of the literature on smoking, alcohol, drug abuse and gambling. 2010.
Jaana M, Pare G. Home telemonitoring of patients with diabetes: a systematic assessment of observed effects. J Eval Clin Pract. 2007;13(2):242-53. [pmid: 17378871].
Johansson T, Wild C. Telemedicine in acute stroke management: systematic review. Int J Technol Assess Health Care. 2010;26(2):149-55. [pmid: 20392317].
Johansson T, Wild C. Telerehabilitation in stroke care--a systematic review. J Telemed Telecare. 2011;17(1):1-6. [pmid: 21097560].
Joint Task Force for the Development of Telepsychology Guidelines for P. Guidelines for the practice of telepsychology. Am Psychol. 2013;68(9):791-800. [pmid: 24341643].
Jones KR, Lekhak N, Kaewluang N. Using mobile phones and short message service to deliver self-management interventions for chronic conditions: a meta-review. Worldviews Evid Based Nurs. 2014;11(2):81-8. [pmid: 24597522].
Kasckow J, Felmet K, Appelt C, et al. Telepsychiatry in the assessment and treatment of schizophrenia. Clin Schizophr Relat Psychoses. 2014;8(1):21-7A. [pmid: 23428781].
Kauer SD, Mangan C, Sanci L. Do online mental health services improve help-seeking for young people? A systematic review. J Med Internet Res. 2014;16(3):e66. [pmid: 24594922].
Khan F, Amatya B, Kesselring J, et al. Telerehabilitation for persons with multiple sclerosis. Cochrane Database Syst Rev. 2015;(4).
Kirk S, Beatty S, Callery P, et al. The effectiveness of self-care support interventions for children and young people with long-term conditions: a systematic review. Child Care Health Dev. 2013;39(3):305-24. [pmid: 22676438].
Klasnja P, Pratt W. Healthcare in the pocket: mapping the space of mobile-phone health interventions. J Biomed Inform. 2012;45(1):184-98. [pmid: 21925288].
Klersy C, De Silvestri A, Gabutti G, et al. Economic impact of remote patient monitoring: an integrated economic model derived from a meta-analysis of randomized controlled trials in heart failure. Eur J Heart Fail. 2011;13(4):450-9. [pmid: 21193439].
Klersy C, De Silvestri A, Gabutti G, et al. A meta-analysis of remote monitoring of heart failure patients. J Am Coll Cardiol. 2009;54(18):1683-94. [pmid: 19850208].
Krishna S, Boren SA, Balas EA. Healthcare via cell phones: a systematic review. Telemed J E Health. 2009;15(3):231-40. [pmid: 19382860].
Kumar S, Merchant S, Reynolds R. Tele-ICU: efficacy and cost-effectiveness of remotely managing critical care. Perspect. 2013;10:1f. [pmid: 23805066].
Lal S, Adair CE. E-mental health: a rapid review of the literature. Psychiatr Serv. 2014;65(1):24-32. [pmid: 24081188].
Laplante C, Peng W. A systematic review of e-health interventions for physical activity: an analysis of study design, intervention characteristics, and outcomes. Telemed J E Health. 2011;17(7):509-23. [pmid: 21718092].
Lewis ER, Thomas CA, Wilson ML, et al. Telemedicine in acute-phase injury management: a review of practice and advancements. Telemed J E Health. 2012;18(6):434-45. [pmid: 22694296].
Lilly CM, Zubrow MT, Kempner KM, et al. Critical care telemedicine: evolution and state of the art. Crit Care Med. 2014;42(11):2429-36. [pmid: 25080052].
Linn AJ, Vervloet M, van Dijk L, et al. Effects of eHealth interventions on medication adherence: a systematic review of the literature. J Med Internet Res. 2011;13(4):e103. [pmid: 22138112].
Liu S, Dunford SD, Leung YW, et al. Reducing blood pressure with Internet-based interventions: a meta-analysis. Can J Cardiol. 2013;29(5):613-21. [pmid: 23618507].
Ludwig W, Wolf K-H, Duwenkamp C, et al. Health-enabling technologies for the elderly--an overview of services based on a literature review. Comput Methods Programs Biomed. 2012;106(2):70-8. [pmid: 22115611].
Macea DD, Gajos K, Daglia Calil YA, et al. The efficacy of Web-based cognitive behavioral interventions for chronic pain: a systematic review and meta-analysis. J Pain. 2010;11(10):917-29. [pmid: 20650691].
Marcolino MS, Maia JX, Alkmim MBM, et al. Telemedicine application in the care of diabetes patients: systematic review and meta-analysis. PLoS ONE. 2013;8(11):e79246. [pmid: 24250826].
Maric B, Kaan A, Ignaszewski A, et al. A systematic review of telemonitoring technologies in heart failure. Eur J Heart Fail. 2009;11(5):506-17. [pmid: 19332417].
Martin S, Kelly G, Kernohan GW, et al. Smart home technologies for health and social care support. Cochrane Database Syst Rev. 2009;(1).
Mathur A, Kvedar JC, Watson AJ. Connected health: a new framework for evaluation of communication technology use in care improvement strategies for type 2 diabetes. Curr Diabetes Rev. 2007;3(4):229-34. [pmid: 18220678].
McGeary DD, McGeary CA, Gatchel RJ. A comprehensive review of telehealth for pain management: where we are and the way ahead. Pain pract. 2012;12(7):570-7. [pmid: 22303839].
McGeary DD, McGeary CA, Gatchel RJ, et al. Assessment of research quality of telehealth trials in pain management: a meta-analysis. Pain pract. 2013;13(5):422-31. [pmid: 23017210].
McLean S, Chandler D, Nurmatov U, et al. Telehealthcare for asthma. Cochrane Database Syst Rev. 2010;(10). CD007717. [pmid: 20927763].
McLean S, Chandler D, Nurmatov U, et al. Telehealthcare for asthma. Cochrane Database Syst Rev. 2012;(8). [pmid: 20927763].
McLean S, Nurmatov U, Liu LYJ, et al. Telehealthcare for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2012;(8). [pmid: 23211177].
Meyer B, Atherton H, Sawmynaden P, et al. Email for communicating results of diagnostic medical investigations to patients. Cochrane Database Syst Rev. 2012;8. CD007980. [pmid: 22895970].
Moffatt JJ, Eley DS. The reported benefits of telehealth for rural Australians. Aust Health Rev. 2010;34(3):276-81. [pmid: 20797357].
Moorhead SA, Hazlett DE, Harrison L, et al. A new dimension of health care: systematic review of the uses, benefits, and limitations of social media for health communication. J Med Internet Res. 2013;15(4):e85. [pmid: 23615206].
Morrison D, Wyke S, Agur K, et al. Digital asthma self-management interventions: a systematic review. J Med Internet Res. 2014;16(2):e51. [pmid: 24550161].
Morrison LG, Yardley L, Powell J, et al. What design features are used in effective e-health interventions? A review using techniques from Critical Interpretive Synthesis. Telemed J E Health. 2012;18(2):137-44. [pmid: 22381060].
Munro J, Angus N, Leslie SJ. Patient focused Internet-based approaches to cardiovascular rehabilitation--a systematic review. J Telemed Telecare. 2013;19(6):347-53. [pmid: 24163299].
Musiat P, Tarrier N. Collateral outcomes in e-mental health: a systematic review of the evidence for added benefits of computerized cognitive behavior therapy interventions for mental health. Psychol Med. 2014;44(15):3137-50. [pmid: 25065947].
Myung S-K, McDonnell DD, Kazinets G, et al. Effects of Web- and computer-based smoking cessation programs: meta-analysis of randomized controlled trials. Arch Intern Med. 2009;169(10):929-37. [pmid: 19468084].
Nakamura N, Koga T, Iseki H. A meta-analysis of remote patient monitoring for chronic heart failure patients. J Telemed Telecare. 2014;20(1):11-7. [pmid: 24352899].
Neubeck L, Redfern J, Fernandez R, et al. Telehealth interventions for the secondary prevention of coronary heart disease: a systematic review. Eur J Cardiovasc Prev Rehabil. 2009;16(3):281-9. [pmid: 19407659].
Neuhauser L, Kreps GL. Online cancer communication: meeting the literacy, cultural and linguistic needs of diverse audiences. Patient Educ Couns. 2008;71(3):365-77. [pmid: 18424046].
Neve M, Morgan PJ, Jones PR, et al. Effectiveness of web-based interventions in achieving weight loss and weight loss maintenance in overweight and obese adults: a systematic review with meta-analysis. Obes Rev. 2010;11(4):306-21. [pmid: 19754633].
New England Healthcare Institute. Critical care, critical choices the case for tele-ICUs in intensive care. 2010.
Nglazi MD, Bekker L-G, Wood R, et al. Mobile phone text messaging for promoting adherence to anti-tuberculosis treatment: a systematic review. BMC Infect Dis. 2013;13:566. [pmid: 24295439].
Ohinmaa A. What lessons can be learned from telemedicine programmes in other countries?. J Telemed Telecare. Suppl 2. 2006;12:S40-4. [pmid: 16989673].
Ohinmaa A, Chatterley P, Nguyen T, et al. Telehealth in substance abuse and addiction: review of the literature on smoking, alcohol, drug abuse and gambling. 2010. PMID.
Oliver DP, Demiris G, Wittenberg-Lyles E, et al. A systematic review of the evidence base for telehospice. Telemed J E Health. 2012;18(1):38-47. [pmid: 22085114].
Omboni S, Gazzola T, Carabelli G, et al. Clinical usefulness and cost effectiveness of home blood pressure telemonitoring: meta-analysis of randomized controlled studies. J Hypertens. 2013;31(3):455-67. discussion 67-8. [pmid: 23299557].
Omboni S, Guarda A. Impact of home blood pressure telemonitoring and blood pressure control: a meta-analysis of randomized controlled studies. American journal of hypertension. 2011;24(9):989-98. PMID. [pmid: 21654858].
O'Reilly GA, Spruijt-Metz D. Current mHealth technologies for physical activity assessment and promotion. Am J Prev Med. 2013;45(4):501-7. [pmid: 24050427].
Orwat C, Graefe A, Faulwasser T. Towards pervasive computing in health care - a literature review. BMC Med Inform Decis Mak. 2008;8:26. [pmid: 18565221].
Osborn CY, Mayberry LS, Mulvaney SA, et al. Patient web portals to improve diabetes outcomes: a systematic review. Curr Diab Rep. 2010;10(6):422-35. [pmid: 20890688].
Osenbach JE, O'Brien KM, Mishkind M, et al. Synchronous telehealth technologies in psychotherapy for depression: a meta-analysis. Depress Anxiety. 2013;30(11):1058-67. [pmid: 23922191].
Pandor A, Thokala P, Gomersall T, et al. Home telemonitoring or structured telephone support programmes after recent discharge in patients with heart failure: systematic review and economic evaluation. Health Technol Assess. 2013;17(32):1-207. v. vi. [pmid: 23927840].
Pare G, Jaana M, Sicotte C. Systematic review of home telemonitoring for chronic diseases: the evidence base. J Am Med Inform Assoc. 2007;14(3):269-77. [pmid: 17329725].
Pare G, Moqadem K, Pineau G, et al. Clinical effects of home telemonitoring in the context of diabetes, asthma, heart failure and hypertension: a systematic review. J Med Internet Res. 2010;12(2):e21. [pmid: 20554500].
Park LG, Howie-Esquivel J, Dracup K. A quantitative systematic review of the efficacy of mobile phone interventions to improve medication adherence. J Adv Nurs. 2014;70(9):1932-53. [pmid: 24689978].
Pate B. A systematic review of the effectiveness of breastfeeding intervention delivery methods. J Obstet Gynecol Neonatal Nurs. 2009;38(6):642-53. [pmid: 19930278].
Paul CL, Carey ML, Sanson-Fisher RW, et al. The impact of web-based approaches on psychosocial health in chronic physical and mental health conditions. Health Educ Res. 2013;28(3):450-71. [pmid: 23660463].
Pellowski JA, Kalichman SC. Recent advances (2011-2012) in technology-delivered interventions for people living with HIV. Curr HIV/AIDS Rep. 2012;9(4):326-34. [pmid: 22922945].
Pereira K, Phillips B, Johnson C, et al. Internet delivered diabetes self-management education: a review. Diabetes Technol Ther. 2015;17(1):55-63. [pmid: 25238257].
Pezzella FR, Pozzessere C, Siniscalchi A, et al. The cloud stroke unit: 24-hour acute stroke expertise-on-demand. Hosp Top. 2013;91(4):81-6. [pmid: 24255936].
Pol MC, Poerbodipoero S, Robben S, et al. Sensor monitoring to measure and support daily functioning for independently living older people: a systematic review and road map for further development. J Am Geriatr Soc. 2013;61(12):2219-27. [pmid: 24479150].
Polisena J, Coyle D, Coyle K, et al. Home telehealth for chronic disease management: a systematic review and an analysis of economic evaluations. Int J Technol Assess Health Care. 2009;25(3):339-49. [pmid: 19619353].
Polisena J, Tran K, Cimon K, et al. Home telehealth for diabetes management: a systematic review and meta-analysis. Diabetes Obes Metab. 2009;11(10):913-30. [pmid: 19531058].
Polisena J, Tran K, Cimon K, et al. Home telehealth for chronic obstructive pulmonary disease: a systematic review and meta-analysis. J Telemed Telecare. 2010;16(3):120-7. [pmid: 20197355].
Polisena J, Tran K, Cimon K, et al. Home telemonitoring for congestive heart failure: a systematic review and meta-analysis. J Telemed Telecare. 2010;16(2):68-76. [pmid: 20008054].
Price CI, Clement F, Gray J, et al. Systematic review of stroke thrombolysis service configuration. Expert rev. 2009;9(2):211-33. [pmid: 19210196].
Pron G, Ieraci L, Kaulback K, et al. Internet-based device-assisted remote monitoring of cardiovascular implantable electronic devices: an evidence-based analysis. Ont Health Technol Assess Ser. 2012;12(1):1-86. [pmid: 23074419].
Purcell R, McInnes S, Halcomb EJ. Telemonitoring can assist in managing cardiovascular disease in primary care: a systematic review of systematic reviews. BMC Fam Pract. 2014;15:43. [pmid: 24606887].
Radhakrishnan K, Jacelon C. Impact of telehealth on patient self-management of heart failure: a review of literature. J Cardiovasc Nurs. 2012;27(1):33-43. [pmid: 21558862].
RAND Corporation. Health and well-being in the home a global analysis of needs, expectations, and priorities for home health care technology. 2010.
Reardon T. Research findings and strategies for assessing telemedicine costs. Telemed J E Health. 2005;11(3):348-69. [pmid: 16035931].
Reger MA, Gahm GA. A meta-analysis of the effects of internet- and computer-based cognitive-behavioral treatments for anxiety. J Clin Psychol. 2009;65(1):53-75. [pmid: 19051274].
Richards D, Vigano N. Online counseling: a narrative and critical review of the literature. J Clin Psychol. 2013;69(9):994-1011. [pmid: 23630010].
Richardson T, Stallard P, Velleman S. Computerised cognitive behavioural therapy for the prevention and treatment of depression and anxiety in children and adolescents: a systematic review. Clin Child Fam Psychol Rev. 2010;13(3):275-90. [pmid: 20532980].
Riper H, Blankers M, Hadiwijaya H, et al. Effectiveness of guided and unguided low-intensity internet interventions for adult alcohol misuse: a meta-analysis. PLoS ONE. 2014;9(6):e99912. [pmid: 24937483].
Rogante M, Grigioni M, Cordella D, et al. Ten years of telerehabilitation: A literature overview of technologies and clinical applications. NeuroRehabilitation. 2010;27(4):287-304. [pmid: 21160118].
Rojas SV, Gagnon M-P. A systematic review of the key indicators for assessing telehomecare cost-effectiveness. Telemed J E Health. 2008;14(9):896-904. [pmid: 19035798].
Rosser BA, Vowles KE, Keogh E, et al. Technologically-assisted behaviour change: a systematic review of studies of novel technologies for the management of chronic illness. J Telemed Telecare. 2009;15(7):327-38. [pmid: 19815901].
RUPRI Center for Rural Health Policy Analysis UoIW, Marcia, Jaana Mirou, Natafgi Nabil. A Systematic Review of the Literature on Tele-Emergency Performance Measurement and A Library of Potential Tele-Emergency Performance Measures. 2015:1-64. PMID.
Russell-Minda E, Jutai J, Speechley M, et al. Health technologies for monitoring and managing diabetes: a systematic review. J Diabetes Sci Technol. 2009;3(6):1460-71. [pmid: 20144402].
Sahu M, Grover A, Joshi A. Role of mobile phone technology in health education in Asian and African countries: a systematic review. Int. 2014;7(4):269-86. [pmid: 25161104].
Sawmynaden P, Atherton H, Majeed A, et al. Email for the provision of information on disease prevention and health promotion. Cochrane Database Syst Rev. 2012;11. CD007982. [pmid: 23152250].
Schlachta-Fairchild L, Elfrink V, Deickman A. Patient Safety, Telenursing, and Telehealth.
Schmidt S, Schuchert A, Krieg T, et al. Home telemonitoring in patients with chronic heart failure: a chance to improve patient care?. Dtsch. 2010;107(8):131-8. [pmid: 20300221].
Schwamm LH, Holloway RG, Amarenco P, et al. A review of the evidence for the use of telemedicine within stroke systems of care: a scientific statement from the American Heart Association/American Stroke Association. Stroke. 2009;40(7):2616-34. [pmid: 19423852].
Shahab L, McEwen A. Online support for smoking cessation: a systematic review of the literature. Addiction. 2009;104(11):1792-804. [pmid: 19832783].
Shahpori R, Kushniruk A, Hebert M, et al. Tele-ICU - a Canadian review. Stud Health Technol Inform. 2011;164:420-4. [pmid: 21335747].
Shalowitz DI, Smith AG, Bell MC, et al. Teleoncology for gynecologic cancers. Gynecol Oncol. 2015;139(1):172-7. [pmid: 26151077].
Shore J, Kaufmann LJ, Brooks E, et al. Review of American Indian veteran telemental health. Telemed J E Health. 2012;18(2):87-94. [pmid: 22283396].
Shulman RM, O'Gorman CS, Palmert MR. The impact of telemedicine interventions involving routine transmission of blood glucose data with clinician feedback on metabolic control in youth with type 1 diabetes: a systematic review and meta-analysis. Int J Ped Endocrinol. 2010. [pmid: 20886054].
Siriwardena LSAN, Wickramasinghe WAS, Perera KLD, et al. A review of telemedicine interventions in diabetes care. J Telemed Telecare. 2012;18(3):164-8. [pmid: 22362832].
Smith AJ, Skow A, Bodurtha J, et al. Health information technology in screening and treatment of child obesity: a systematic review. Pediatrics. 2013;131(3):e894-902. [pmid: 23382447].
Stewart SF, Switzer JA. Perspectives on telemedicine to improve stroke treatment. Drugs Today (Barc). 2011;47(2):157-67. [pmid: 21431103].
Stip E, Rialle V. Environmental cognitive remediation in schizophrenia: ethical implications of “smart home” technology. Can J Psychiatry. 2005;50(5):281-91. [pmid: 15968845].
Swanepoel DW, Hall JW 3rd. A systematic review of telehealth applications in audiology. Telemed J E Health. 2010;16(2):181-200. [pmid: 20187743].
Tait RJ, Spijkerman R, Riper H. Internet and computer based interventions for cannabis use: a meta-analysis. Drug Alcohol Depend. 2013;133(2):295-304. [pmid: 23747236].
Tildesley HD, Po MD, Ross SA. Internet blood glucose monitoring systems provide lasting glycemic benefit in type 1 and 2 diabetes: a systematic review. Med Clin North Am. 2015;99(1):17-33. [pmid: 25456641].
Tomlinson M, Rotheram-Borus MJ, Swartz L, et al. Scaling up mHealth: where is the evidence?. PLoS Med. 2013;10(2):e1001382. [pmid: 23424286].
Tsimicalis A, De Courcy MJ, Di Monte B, et al. Tele-practice guidelines for the symptom management of children undergoing cancer treatment. Pediatr Blood Cancer. 2011;57(4):541-8. [pmid: 21319280].
Urquhart C, Currell R. Home uterine monitoring: a case of telemedicine failure?. Health Informatics J. 2010;16(3):165-75. [pmid: 20889847].
Valimaki M, Hatonen H, Lahti M, et al. Information and communication technology in patient education and support for people with schizophrenia. Cochrane Database Syst Rev. 2012;(10).
van den Berg N, Schumann M, Kraft K, et al. Telemedicine and telecare for older patients--a systematic review. Maturitas. 2012;73(2):94-114. [pmid: 22809497].
van der Heijden JP, Spuls PI, Voorbraak FP, et al. Tertiary teledermatology: a systematic review. Telemed J E Health. 2010;16(1):56-62. [pmid: 20064068].
van Gurp J, Hasselaar J, van Leeuwen E, et al. Connecting with patients and instilling realism in an era of emerging communication possibilities: a review on palliative care communication heading to telecare practice. Patient Educ Couns. 2013;93(3):504-14. [pmid: 23906650].
Vedel I, Akhlaghpour S, Vaghefi I, et al. Health information technologies in geriatrics and gerontology: a mixed systematic review. J Am Med Inform Assoc. 2013;20(6):1109-19. [pmid: 23666776].
Vegting IL, Schrijver EJM, Otten RHJ, et al. Internet programs targeting multiple lifestyle interventions in primary and secondary care are not superior to usual care alone in improving cardiovascular risk profile: a systematic review. Eur. 2014;25(1):73-81. [pmid: 24011771].
Ventura F, Ohlen J, Koinberg I. An integrative review of supportive e-health programs in cancer care. Eur J Oncol Nurs. 2013;17(4):498-507. [pmid: 23158437].
Verhoeven F, Tanja-Dijkstra K, Nijland N, et al. Asynchronous and synchronous teleconsultation for diabetes care: a systematic literature review. J Diabetes Sci Technol. 2010;4(3):666-84. [pmid: 20513335].
Verhoeven F, van Gemert-Pijnen L, Dijkstra K, et al. The contribution of teleconsultation and videoconferencing to diabetes care: a systematic literature review. J Med Internet Res. 2007;9(5):e37. [pmid: 18093904].
Ward MM, Jaana M, Natafgi N. A Systematic Review of the Literature on Tele-Emergency Performance Measurement and A Library of Potential Tele-Emergency Performance Measures. Mathematica Policy Research. 2015.
Wei I, Pappas Y, Car J, et al. Computer-assisted versus oral-and-written dietary history taking for diabetes mellitus. Cochrane Database Syst Rev. 2011;(12).
White A, Kavanagh D, Stallman H, et al. Online alcohol interventions: a systematic review. J Med Internet Res. 2010;12(5):e62. [pmid: 21169175].
Wickham CA, Carbone ET. Who's calling for weight loss? A systematic review of mobile phone weight loss programs for adolescents. Nutrition Reviews. 2015;73(6):386-98. [pmid: 26011913].
Wootton R. Twenty years of telemedicine in chronic disease management--an evidence synthesis. J Telemed Telecare. 2012;18(4):211-20. [pmid: 22674020].
Wootton R, Bahaadinbeigy K, Hailey D. Estimating travel reduction associated with the use of telemedicine by patients and healthcare professionals: proposal for quantitative synthesis in a systematic review. BMC Health Serv Res. 2011;11:185. [pmid: 21824388].
World Health Organization. Building foundations for eHealth: progress of member states: report of the WHO Global Observatory for eHealth. 2006.
World Health Organization. How can telehealth help in the provision of integrated care?. 2010.
Worswick J, Wayne SC, Bennett R, et al. Improving quality of care for persons with diabetes: an overview of systematic reviews - what does the evidence tell us?. Syst. 2013;2:26. [pmid: 23647654].
Xiang R, Li L, Liu SX. Meta-analysis and meta-regression of telehealth programmes for patients with chronic heart failure. J Telemed Telecare. 2013;19(5):249-59. [pmid: 24163234].
Ye X, Bapuji SB, Winters SE, et al. Effectiveness of internet-based interventions for children, youth, and young adults with anxiety and/or depression: a systematic review and meta-analysis. BMC Health Serv Res. 2014;14:313. [pmid: 25037951].
Young LB. Telemedicine interventions for substance-use disorder: a literature review. J Telemed Telecare. 2012;18(1):47-53. [pmid: 22101610].
Young LB, Chan PS, Lu X, et al. Impact of telemedicine intensive care unit coverage on patient outcomes: a systematic review and meta-analysis. Arch Intern Med. 2011;171(6):498-506. [pmid: 21444842].
Yu CH, Bahniwal R, Laupacis A, et al. Systematic review and evaluation of web-accessible tools for management of diabetes and related cardiovascular risk factors by patients and healthcare providers. J Am Med Inform Assoc. 2012;19(4):514-22. [pmid: 22215057].