# Included Studies

Ammenwerth E, Schnell-Inderst P, Hoerbst A. The impact of electronic patient portals on patient care: a systematic review of controlled trials. J Med Internet Res. 2012;14(6):e162. [pmid: 23183044].
Antonacci DJ, Bloch RM, Saeed SA, et al. Empirical evidence on the use and effectiveness of telepsychiatry via videoconferencing: implications for forensic and correctional psychiatry. Behav Sci Law. 2008;26(3):253-69. [pmid: 18548519].
Antoniou SA, Antoniou GA, Franzen J, et al. A comprehensive review of telementoring applications in laparoscopic general surgery. Surg Endosc. 2012;26(8):2111-6. [pmid: 22350150].
Chaudhry SI, Phillips CO, Stewart SS, et al. Telemonitoring for patients with chronic heart failure: a systematic review. J Card Fail. 2007;13(1):56-62. [pmid: 17339004].
Clark RA, Conway A, Poulsen V, et al. Alternative models of cardiac rehabilitation: a systematic review. Eur J Prev Cardiolog. 2015;22(1):35-74. [pmid: 23943649].
Clarke M, Shah A, Sharma U. Systematic review of studies on telemonitoring of patients with congestive heart failure: a meta-analysis. J Telemed Telecare. 2011;17(1):7-14. [pmid: 21097564].
Connelly J, Kirk A, Masthoff J, et al. The use of technology to promote physical activity in Type 2 diabetes management: a systematic review. Diabet Med. 2013;30(12):1420-32. [pmid: 23870009].
Conway A, Inglis SC, Clark RA. Effective technologies for noninvasive remote monitoring in heart failure. Telemed J E Health. 2014;20(6):531-8. [pmid: 24731212].
Cox NS, Alison JA, Rasekaba T, et al. Telehealth in cystic fibrosis: a systematic review. J Telemed Telecare. 2012;18(2):72-8. [pmid: 22198961].
Cruz J, Brooks D, Marques A. Home telemonitoring effectiveness in COPD: a systematic review. Int J Clin Pract Suppl. 2014;68(3):369-78. [pmid: 24472009].
Dang S, Dimmick S, Kelkar G. Evaluating the evidence base for the use of home telehealth remote monitoring in elderly with heart failure. Telemed J E Health. 2009;15(8):783-96. [pmid: 19831704].
de Jong CC, Ros WJ, Schrijvers G. The effects on health behavior and health outcomes of Internet-based asynchronous communication between health providers and patients with a chronic condition: a systematic review. J Med Internet Res. 2014;16(1):e19. [pmid: 24434570].
de Waure C, Cadeddu C, Gualano MR, et al. Telemedicine for the reduction of myocardial infarction mortality: a systematic review and a meta-analysis of published studies. Telemed J E Health. 2012;18(5):323-8. [pmid: 22468983].
Devi R, Singh SJ, Powell J, et al. Internet-based interventions for the secondary prevention of coronary heart disease. Cochrane Database Syst Rev. 2015;(12). [pmid: 26691216].
dos Santos MT, Moura SC, Gomes LM, et al. Telehealth application on the rehabilitation of children and adolescents. Rev Paul Pediatr. 2014;32(1):136-43. [pmid: 24676201].
Eccleston C, Fisher E, Craig L, et al. Psychological therapies (Internet-delivered) for the management of chronic pain in adults. Cochrane Database Syst Rev. 2014;2. CD010152. [pmid: 24574082].
Eland-de Kok P, van Os-Medendorp H, Vergouwe-Meijer A, et al. A systematic review of the effects of e-health on chronically ill patients. J Clin Nurs. 2011;20(21-22):2997-3010. [pmid: 21707807].
Flodgren G, Rachas A, Farmer AJ, et al. Interactive telemedicine: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2015;(9). [pmid: 26343551].
Gaikwad R, Warren J. The role of home-based information and communications technology interventions in chronic disease management: a systematic literature review. Health Inform J. 2009;15(2):122-46. [pmid: 19474225].
Gainsbury S, Blaszczynski A. A systematic review of Internet-based therapy for the treatment of addictions. Clin Psychol Rev. 2011;31(3):490-8. [pmid: 21146272].
Garcia-Lizana F, Sarria-Santamera A. New technologies for chronic disease management and control: a systematic review. J Telemed Telecare. 2007;13(2):62-8. [pmid: 17359568].
Hailey D, Roine R, Ohinmaa A, et al. Evidence on the effectiveness of telerehabilition applications. 2010.
Holtz B, Lauckner C. Diabetes management via mobile phones: a systematic review. Telemed J E Health. 2012;18(3):175-84. [pmid: 22356525].
Jaana M, Pare G, Sicotte C. Home telemonitoring for respiratory conditions: a systematic review. Am J Manag Care. 2009;15(5):313-20. [pmid: 19435399].
Johansen MA, Berntsen GKR, Schuster T, et al. Electronic symptom reporting between patient and provider for improved health care service quality: a systematic review of randomized controlled trials. part 2: methodological quality and effects. J Med Internet Res. 2012;14(5):e126. [pmid: 23032363].
Kairy D, Lehoux P, Vincent C, et al. A systematic review of clinical outcomes, clinical process, healthcare utilization and costs associated with telerehabilitation. Disabil Rehabil. 2009;31(6):427-47. [pmid: 18720118].
Kamei T, Yamamoto Y, Kajii F, et al. Systematic review and meta-analysis of studies involving telehome monitoring-based telenursing for patients with chronic obstructive pulmonary disease. Jpn J Nurs Sci. 2013;10(2):180-92. [pmid: 24373441].
Knowles SR, Mikocka-Walus A. Utilization and efficacy of internet-based eHealth technology in gastroenterology: a systematic review. Scand J Gastroenterol. 2014;49(4):387-408. [pmid: 24494974].
Kodama S, Saito K, Tanaka S, et al. Effect of Web-based lifestyle modification on weight control: a meta-analysis. Int J Obes (Lond). 2012;36(5):675-85. [pmid: 21694698].
Kotb A, Cameron C, Hsieh S, et al. Comparative effectiveness of different forms of telemedicine for individuals with heart failure (HF): a systematic review and network meta-analysis. PLoS ONE. 2015;10(2):e0118681. [pmid: 25714962].
Kumar G, Falk DM, Bonello RS, et al. The costs of critical care telemedicine programs: a systematic review and analysis. Chest. 2013;143(1):19-29. [pmid: 22797291].
Laver KE, Schoene D, Crotty M, et al. Telerehabilitation services for stroke. Cochrane Database Syst Rev. 2013;12. CD010255. [pmid: 24338496].
Liang X, Wang Q, Yang X, et al. Effect of mobile phone intervention for diabetes on glycaemic control: a meta-analysis. Diabet Med. 2011;28(4):455-63. [pmid: 21392066].
Lustria MLA, Noar SM, Cortese J, et al. A meta-analysis of web-delivered tailored health behavior change interventions. [Erratum appears in J Health Commun. 2013;18(11):1397]. J Health Commun. 2013;18(9):1039-69. [pmid: 23750972].
Martin S, Sutcliffe P, Griffiths F, et al. Effectiveness and impact of networked communication interventions in young people with mental health conditions: a systematic review. Patient Educ Couns. 2011;85(2):e108-19. [pmid: 21239133].
McLean S, Nurmatov U, Liu JL, et al. Telehealthcare for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2011;(7). CD007718. [pmid: 21735417].
Merriel SWD, Andrews V, Salisbury C. Telehealth interventions for primary prevention of cardiovascular disease: a systematic review and meta-analysis. Prev Med. 2014;64:88-95. [pmid: 24726502].
Moy MF, Ray A, Buckley BS. Techniques of monitoring blood glucose during pregnancy for women with pre-existing diabetes. Cochrane Database Syst Rev. 2015;(11). [pmid: 24782359].
Parthiban N, Esterman A, Mahajan R, et al. Remote Monitoring of Implantable Cardioverter-Defibrillators: A Systematic Review and Meta-Analysis of Clinical Outcomes. J Am Coll Cardiol. 2015;65(24):2591-600. [pmid: 25983009].
Peeters JM, Mistiaen P, Francke AL. Costs and financial benefits of video communication compared to usual care at home: a systematic review. J Telemed Telecare. 2011;17(8):403-11. [pmid: 22025744].
Ramadas A, Quek KF, Chan CKY, et al. Web-based interventions for the management of type 2 diabetes mellitus: a systematic review of recent evidence. Int J Med Inf. 2011;80(6):389-405. [pmid: 21481632].
Richards D, Richardson T. Computer-based psychological treatments for depression: a systematic review and meta-analysis. Clin Psychol Rev. 2012;32(4):329-42. [pmid: 22466510].
Rietdijk R, Togher L, Power E. Supporting family members of people with traumatic brain injury using telehealth: a systematic review. J Rehabil Med. 2012;44(11):913-21. [pmid: 23027316].
Rooke S, Thorsteinsson E, Karpin A, et al. Computer-delivered interventions for alcohol and tobacco use: a meta-analysis. Addiction. 2010;105(8):1381-90. [pmid: 20528806].
Rooksby M, Elouafkaoui P, Humphris G, et al. Internet-assisted delivery of cognitive behavioural therapy (CBT) for childhood anxiety: systematic review and meta-analysis. JAnxiety Dis. 2015;29:83-92. [pmid: 25527900].
Saffari M, Ghanizadeh G, Koenig HG. Health education via mobile text messaging for glycemic control in adults with type 2 diabetes: a systematic review and meta-analysis. Primary care diabetes. 2014;8(4):275-85. [pmid: 24793589].
Seto E. Cost comparison between telemonitoring and usual care of heart failure: a systematic review. Telemed J E Health. 2008;14(7):679-86. [pmid: 18817497].
Steel K, Cox D, Garry H. Therapeutic videoconferencing interventions for the treatment of long-term conditions. J Telemed Telecare. 2011;17(3):109-17. [pmid: 21339304].
Tan K, Lai NM. Telemedicine for the support of parents of high-risk newborn infants. Cochrane Database Syst Rev. 2012;6. CD006818. [pmid: 22696360].
Toma T, Athanasiou T, Harling L, et al. Online social networking services in the management of patients with diabetes mellitus: systematic review and meta-analysis of randomised controlled trials. Diabetes Res Clin Pract. 2014;106(2):200-11. [pmid: 25043399].
Tran K, Drugs CAf, Health Ti. Home telehealth for chronic disease management: Canadian Agency for Drugs and Technologies in Health Ottawa. 2008.
Urquhart C, Currell R, Harlow F, et al. Home uterine monitoring for detecting preterm labour. Cochrane Database Syst Rev. 2015.
van Beugen S, Ferwerda M, Hoeve D, et al. Internet-based cognitive behavioral therapy for patients with chronic somatic conditions: a meta-analytic review. J Med Internet Res. 2014;16(3):e88. [pmid: 24675372].
Wade VA, Karnon J, Elshaug AG, et al. A systematic review of economic analyses of telehealth services using real time video communication. BMC Health Serv Res. 2010;10:233. [pmid: 20696073].
Wallace DL, Hussain A, Khan N, et al. A systematic review of the evidence for telemedicine in burn care: with a UK perspective. Burns. 2012;38(4):465-80. [pmid: 22078804].
Warshaw EM, Hillman YJ, Greer NL, et al. Teledermatology for diagnosis and management of skin conditions: a systematic review. J Am Acad Dermatol. 2011;64(4):759-72. [pmid: 21036419].
Widmer RJ, Collins NM, Collins CS, et al. Digital health interventions for the prevention of cardiovascular disease: a systematic review and meta-analysis. Mayo Clin Proc. 2015;90(4):469-80. [pmid: 25841251].
Zhai Y-k, Zhu W-j, Cai Y-l, et al. Clinical- and cost-effectiveness of telemedicine in type 2 diabetes mellitus: a systematic review and meta-analysis. Medicine (Baltimore). 2014;93(28):e312. [pmid: 25526482].