# Inclusion Criteria for Systematic Reviews

Study Designs | INCLUDE: Systematic reviews: Must have conducted literature searches in at least one database AND reported quality for the included papers. EXCLUDE: Nonsystematic reviews, narrative reviews, opinions, letters, primary studies
Populations | INCLUDE: Patients (adult or pediatric) interacting with a provider (physician, nurse, therapist, etc.) over distance or time. Providers interacting without patient interaction when the interaction is directly related to care of a specific patient and not purely for education purposes. Acute and chronic conditions included.
Interventions | INCLUDE: Any telehealth intervention: The use of technology to facilitate an interaction between a patient and the health care system or interaction between two or more providers when the interaction was directly related to an individual patient's care. Interventions could:; - Occur over distance and/or over time (asynchronous and/or real time); - Include video, mobile devices or a variety of technology; EXCLUDE: Any intervention that does not include an interaction between a health professional and patient, or between two health professionals; training/education interventions that do not include a patient; telephone-only interactions
Comparators | Any of the included interventions, usual care
Outcomes | INCLUDE: Clinical Outcomes:; - Mortality; - Morbidity; - Illness; - Test parameters (e.g., HbA1c); Health Care Utilization and Access:; - Hospitalizations (length of stay, readmission); - ER; - Outpatient visits; - Nursing home/rehab; - Reduced travel time; - Time to receipt of care; Cost Effectiveness EXCLUDE: Patient or provider satisfaction, provider concordance, compliance, other nonclinical outcomes, or nonutilization outcomes.
Timing/Setting | INCLUDE: Any setting, including rural or urban, home or community-based care, clinic, radiology, pharmacy, nursing home, or hospital-based care Any duration of followup EXCLUDE: Systematic reviews with search date ranges ending prior to 2005