# Search Strategies

## Searches for systematic reviews

### Ovid MEDLINE (2006 to February 2016)

1. exp Telemedicine/
2. exp Patient Care/
3. exp Therapeutics/
4. exp Health Services/
5. exp Diagnosis/
6. exp Professional-Patient Relations/
7. exp Health Services Accessibility/
8. exp Health Behavior/
9. 2 or 3 or 4 or 5 or 6 or 7 or 8
10. exp *Telecommunications/
11. exp *Computer Communication Networks/
12. 10 or 11
13. 9 and 12
14. 1 or 13
15. limit 14 to english language
16. limit 15 to systematic reviews
17. limit 16 to yr=“2006 -Current”

### Cochrane Database of Systematic Reviews (2005 to February 2016)

1 (telemedic$ or telehealth$ or teleradiol$ or teledermat$).mp.
2 (tele-medic$ or tele-heal$ or tele-radiol$ or tele-dermat$).mp.
4 (emedicine or ehealth or e-medicine or e-health).mp.

## Searches for ongoing systematic reviews

### PROSPERO database (August 1, 2013 to March 2016)

Protocols marked “Ongoing” with the following words in any of the fields: “telehealth” OR “telecare” OR “telemedicine” OR “eHealth” OR “mHealth.”

## Searches for primary research

### Ovid MEDLINE (2005 to August 2015)

1. exp telemedicine
2. telehealth.mp
3. 1 or 2
4. exp cancer
5. exp chronic disease
6. 4 or 5
7. 3 and 6
8. limit 7 to english language
9. limit 8 to yr=“2005 -Current”
10. limit 9 to (“all infant (birth to 23 months)” or “all child (0 to 18 years)”)

------------------------------------------------------------------------

1. exp telemedicine/
2. telehealth.mp.
3. 1 or 2
4. exp Pregnancy/
5. exp Postpartum Period/
6. 4 or 5
7. 3 and 6
8. limit 7 to english language
9. limit 8 to yr=“2005 - 2015”

------------------------------------------------------------------------

1. exp telemedicine/
2. telehealth.mp.
3. 1 or 2
4. ambulatory care.mp. or *Ambulatory Care/
5. urgent care.mp.
6. exp Triage/ or triage.mp.
7. 4 or 5 or 6
8. 3 and 7
9. limit 8 to english language
10. limit 9 to yr=“2005 -Current”

------------------------------------------------------------------------

1. exp telemedicine.mp or exp Telemedicine/
2. *Dermatology/
3. exp Remote Consultation/
4. 1 or 3
5. exp Prognosis/
6. 2 and 4
7. 5 and 6
8. exp Treatment Outcome/
9. 6 and 8

## Search for grey literature

### The New York Academy of Medicine Library Grey Literature Collection (searched on 9.28.2015)

1. Telehealth
2. Telemedicine

### Searches of websites of organizations and federal agencies

Text word searches of the following websites were conducted on 9.28.2015 and 9.29.2015

Agency/Organization | URL
American Telemedicine Association | www.americantelemed.org
United States Department of Health & Human Services | www.hhs.gov
Healthcare Information and Management Systems Society (HIMSS) | www.himss.org
United States Office of the Assistant Secretary for Planning and Evaluation (ASPE) | www.aspe.hhs.gov
Personal Connected Health Alliance | www.pchalliance.org
Centers for Medicare & Medicaid Services (CMS) | www.cms.gov/Medicare/Medicare-General-information/telehealth
The Office of the National Coordinator for Health Information Technology | www.healthit.gov
Wireless-Life Sciences Alliance | www.wirelesslifesciences.org
United States Health Resources and Services Administration | www.hrsa.gov/index.html
National Institute of Standards and Technology | www.nist.gov
United States Department of Veterans Affairs (VA) | www.telehealth.va.gov
Agency for Healthcare Research and Quality (AHRQ) | http://www.ahrq.gov/
Markle Foundation | www.markle.org/
National Center for Telehealth and Technology (T2) | www.t2health.dcoe.mil/programs-telehealth
New York Academy of Medicine Library of Grey Literature | www.greylit.org
California Healthcare Foundation | www.chcf.org