# References

1 Gaynes B, Brown C, Lux LJ, et al. Relationship Between Use of Quality Measures and Improved Outcomes in Serious Mental Illness. Rockville MD. 2015.
2 Peck MC, Scheffler RM. An analysis of the definitions of mental illness used in state parity laws. Psychiatr Serv. Sep. 2002;53(9):1089-95. Epub: 2002/09/11. [pmid: 12221306].
3 National Institute of Mental Health. Schizophrenias. Washington, DC. U.S. Department of Health and Human Services. http://www.nimh.nih.gov/health/statistics/prevalence/schizophrenia.shtml. May 13, 2013.
4 Epstein J, Barker P, Vorburger M, et al. Serious Mental Illness and Its Co-Occurrence with Substance Use Disorders, 2002. Substance Abuse and Mental Health Services Administration, Office of Applied Studies. (DHHS Publication No. SMA 04-3905, Analytic Series A-24). Rockville, MD. 2004.
5 Jonas DE, Cusack K, Forneris CA, et al. Psychological and Pharmacological Treatments for Adults with Posttraumatic Stress Disorder (PTSD). Comparative Effectiveness Review No. 92. (Prepared by the RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I.). AHRQ Publication No. 13-EHC011-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2013.
6 Lawrence D, Kisely S. Inequalities in healthcare provision for people with severe mental illness. Journal of Psychopharmacology. 2010;24(11, Suppl 4):61-8. [pmid: 20923921].
7 Carpenter-Song E, Chu E, Drake RE, et al. Ethno-cultural variations in the experience and meaning of mental illness and treatment: Implications for access and utilization. Transcultural Psychiatry. 2010;47(2):224-51. [pmid: 20603387].
8 Koizumi N, Rothbard AB, Kuno E. Distance matters in choice of mental health program: Policy implications for reducing racial disparities in public mental health care. Administration and Policy in Mental Health and Mental Health Services Research. 2009;36(6):424-31. [pmid: 19653093].
9 Substance Abuse and Mental Health Services Administration. Racial/ Ethnic Differences in Mental Health Service Use among Adults. HHS Publication No. SMA-15-4906. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2015.
10 Agency for Healthcare Research and Quality. National Healthcare Disparities Report: 2009. AHRQ AHRQ Publication No. 10-0004. Rockville, MD. March. 2010. http://archive.ahrq.gov/research/findings/nhqrdr/nhdr09/nhdr09.pdf.
11 Horvitz-Lennon M, Volya R, Donohue J, et al. Disparities in quality of care among publicly insured adults with schizophrenia in four large U.S. States, 2002–2008. Health Serv Res. 2014;49(4):1121-44. [pmid: 24628414].
12 Copeland LA, Zeber JE, Valenstein M, et al. Racial disparity in the use of atypical antipsychotic medications among veterans. Am J Psychiatry. Oct. 2003;160(10):1817-22. Epub: 2003/09/30. [pmid: 14514496].
13 Agency for Healthcare Research and Quality. National Healthcare Disparities Report: 2013. AHRQ AHRQ Publication No. 14-0006. Rockville, MD. March. 2014. www.ahrq.gov/research/findings/nhqrdr/index.html.
14 Institute of Medicine (US) Committee on Lesbian G, Bisexual, and Transgender Health Issues and Research Gaps and Opportunities. The Health of Lesbian, Gay, Bisexual, and Transgender People: Building a Foundation for Better Understanding. Washington DC. National Academy of Sciences. 2011.
15 King M, Semlyen J, Tai SS, et al. A systematic review of mental disorder, suicide, and deliberate self harm in lesbian, gay and bisexual people. BMC Psychiatry. 2008;8:70. Epub: 2008/08/19. [pmid: 18706118].
16 Pence BW, O'Donnell JK, Gaynes BN. The depression treatment cascade in primary care: a public health perspective. Curr Psychiatry Rep. Aug. 2012;14(4):328-35. [pmid: 22580833].
17 Hudley C, Durvasula R, Jones D, et al. Examining the Complexities Between Health Disparities and Poverty. American Psycholoigical Association. Washington DC. March. 2014. https://www.apa.org/pi/ses/resources/poverty-complexities-bibliography.pdf.
18 Miranda J, Lawson W, Escobar J. Ethnic minorities. Ment Health Serv Res. Dec. 2002;4(4):231-7. Epub: 2003/02/01. [pmid: 12558009].
19 Barnes A. Race, schizophrenia, and admission to state psychiatric hospitals. Adm Policy Ment Health. Jan. 2004;31(3):241-52. Epub: 2004/05/27. [pmid: 15160786].
20 DeCoux Hampton M. The role of treatment setting and high acuity in the overdiagnosis of schizophrenia in African Americans. Arch Psychiatr Nurs. 2007;21(6):327-35. [pmid: 18037443].
21 Jonas D, Mansfield AJ, Curtis P, et al. Identifying Priorities for Patient-Centered Outcomes Research for Serious Mental Illness. Rockville MD. 2011.
22 Secretary of Health and Human Services. ADAMHA Reorganization Act. Fed Regist. May. 20. 1993;58(96):29422-5.
23 Morrissey JP, Dennis DL, editors. Homelessness and Mental Illness: Toward the Next Generation of Research Studies. Rockville, MD. National Institutes of Mental Health. 1990.
24 Chong J, Moreno F. Feasibility and acceptability of clinic-based telepsychiatry for low-income Hispanic primary care patients. Telemed J E Health. May. 2012;18(4):297-304. Epub: 2012/03/20. [pmid: 22424078].
25 Arean PA, Ayalon L, Hunkeler E, et al. Improving depression care for older, minority patients in primary care. Med Care. Apr. 2005;43(4):381-90. Epub: 2005/03/22. [pmid: 15778641].
26 Arean PA, Gum AM, Tang L, et al. Service use and outcomes among elderly persons with low incomes being treated for depression. Psychiatr Serv. Aug. 2007;58(8):1057-64. Epub: 2007/08/01. [pmid: 17664516].
27 Cooper LA, Ghods Dinoso BK, Ford DE, et al. Comparative effectiveness of standard versus patient-centered collaborative care interventions for depression among African Americans in primary care settings: the BRIDGE Study. Health Serv Res. Feb. 2013;48(1):150-74. Epub: 2012/06/22. [pmid: 22716199].
28 Interian A, Lewis-Fernandez R, Gara MA, et al. A randomized-controlled trial of an intervention to improve antidepressant adherence among Latinos with depression. Depress Anxiety. Jul. 2013;30(7):688-96. Epub: 2013/01/10. [pmid: 23300127].
29 Lewis-Fernandez R, Balan IC, Patel SR, et al. Impact of motivational pharmacotherapy on treatment retention among depressed Latinos. Psychiatry. Fall. 2013;76(3):210-22. Epub: 2013/08/24. [pmid: 23965261].
30 Miranda J, Chung JY, Green BL, et al. Treating depression in predominantly low-income young minority women: a randomized controlled trial. JAMA. Jul. 2. 2003;290(1):57-65. Epub: 2003/07/03. [pmid: 12837712].
31 Revicki DA, Siddique J, Frank L, et al. Cost-effectiveness of evidence-based pharmacotherapy or cognitive behavior therapy compared with community referral for major depression in predominantly low-income minority women. Arch Gen Psychiatry. Aug. 2005;62(8):868-75. Epub: 2005/08/03. [pmid: 16061764].
32 Moreno FA, Chong J, Dumbauld J, et al. Use of standard Webcam and Internet equipment for telepsychiatry treatment of depression among underserved Hispanics. Psychiatr Serv. Dec. 2012;63(12):1213-7. Epub: 2012/10/03. [pmid: 23026854].
33 O'Mahen H, Himle JA, Fedock G, et al. A pilot randomized controlled trial of cognitive behavioral therapy for perinatal depression adapted for women with low incomes. Depress Anxiety. Jul. 2013;30(7):679-87. Epub: 2013/01/16. [pmid: 23319454].
34 Tsai AC, Karasic DH, Hammer GP, et al. Directly observed antidepressant medication treatment and HIV outcomes among homeless and marginally housed HIV-positive adults: a randomized controlled trial. Am J Public Health. Feb. 2013;103(2):308-15. Epub: 2012/06/23. [pmid: 22720766].
35 Herman DB, Conover S, Gorroochurn P, et al. Randomized trial of critical time intervention to prevent homelessness after hospital discharge. Psychiatr Serv. Jul. 2011;62(7):713-9. Epub: 2011/07/05. [pmid: 21724782].
36 Tomita A, Herman DB. The impact of critical time intervention in reducing psychiatric rehospitalization after hospital discharge. Psychiatr Serv. Sep. 1. 2012;63(9):935-7. Epub: 2012/07/20. [pmid: 22810163].
37 Tomita A, Herman DB. The role of a critical time intervention on the experience of continuity of care among persons with severe mental illness after hospital discharge. J Nerv Ment Dis. Jan. 2015;203(1):65-70. Epub: 2014/12/24. [pmid: 25536101].
38 Tomita A, Lukens EP, Herman DB. Mediation analysis of critical time intervention for persons living with serious mental illnesses: assessing the role of family relations in reducing psychiatric rehospitalization. Psychiatr Rehabil J. Mar. 2014;37(1):4-10. Epub: 2013/11/14. [pmid: 24219767].
39 Susser E, Valencia E, Conover S, et al. Preventing recurrent homelessness among mentally ill men: a “critical time” intervention after discharge from a shelter. Am J Public Health. Feb. 1997;87(2):256-62. Epub: 1997/02/01. [pmid: 9103106].
40 Herman D, Opler L, Felix A, et al. A critical time intervention with mentally ill homeless men: impact on psychiatric symptoms. J Nerv Ment Dis. Mar. 2000;188(3):135-40. Epub: 2000/04/05. [pmid: 10749277].
41 Jones K, Colson PW, Holter MC, et al. Cost-effectiveness of critical time intervention to reduce homelessness among persons with mental illness. Psychiatr Serv. Jun. 2003;54(6):884-90. Epub: 2003/05/30. [pmid: 12773605].
42 Jones K, Colson P, Valencia E, et al. A preliminary cost effectiveness analysis of an intervention to reduce homelessness among the mentally ill. Psychiatr Q. Winter. 1994;65(4):243-56. Epub: 1994/01/01. [pmid: 7831412].
43 Burt MR. Impact of housing and work supports on outcomes for chronically homeless adults with mental illness: LA's HOPE. Psychiatr Serv. Mar. 2012;63(3):209-15. Epub: 2012/02/07. [pmid: 22307878].
44 Kopelowicz A, Zarate R, Wallace CJ, et al. The ability of multifamily groups to improve treatment adherence in Mexican Americans with schizophrenia. Arch Gen Psychiatry. Mar. 2012;69(3):265-73. Epub: 2012/03/07. [pmid: 22393219].
45 Patterson TL, Bucardo J, McKibbin CL, et al. Development and pilot testing of a new psychosocial intervention for older Latinos with chronic psychosis. Schizophr Bull. Oct. 2005;31(4):922-30. Epub: 2005/07/23. [pmid: 16037481].
46 Shin SK, Lukens EP. Effects of psychoeducation for Korean Americans with chronic mental illness. Psychiatr Serv. Sep. 2002;53(9):1125-31. Epub: 2002/09/11. [pmid: 12221311].
47 Telles C, Karno M, Mintz J, et al. Immigrant families coping with schizophrenia. Behavioral family intervention v. case management with a low-income Spanish-speaking population. Br J Psychiatry. Oct. 1995;167(4):473-9. Epub: 1995/10/01. [pmid: 8829715].
48 Lehman AF, Dixon LB, Kernan E, et al. A randomized trial of assertive community treatment for homeless persons with severe mental illness. Arch Gen Psychiatry. Nov. 1997;54(11):1038-43. Epub: 1997/11/21. [pmid: 9366661].
49 Fortney JC, Pyne JM, Kimbrell TA, et al. Telemedicine-based collaborative care for posttraumatic stress disorder: a randomized clinical trial. JAMA Psychiatry. Jan. 2015;72(1):58-67. Epub: 2014/11/20. [pmid: 25409287].
50 Rosenheck R, Morrissey J, Lam J, et al. Service system integration, access to services, and housing outcomes in a program for homeless persons with severe mental illness. Am J Public Health. Nov. 1998;88(11):1610-5. Epub: 1998/11/10. [pmid: 9807525].
51 Rosenheck RA, Lam J, Morrissey JP, et al. Service systems integration and outcomes for mentally ill homeless persons in the ACCESS program. Access to Community Care and Effective Services and Supports. Psychiatr Serv. Aug. 2002;53(8):958-66. Epub: 2002/08/06. [pmid: 12161669].
52 Lam JA, Rosenheck R. Street outreach for homeless persons with serious mental illness: is it effective?. Med Care. Sep. 1999;37(9):894-907. Epub: 1999/09/24. [pmid: 10493468].
53 Rothbard AB, Min SY, Kuno E, et al. Long-term effectiveness of the ACCESS program in linking community mental health services to homeless persons with serious mental illness. J Behav Health Serv Res. Oct-Dec. 2004;31(4):441-9. Epub: 2004/12/17. [pmid: 15602144].
54 Shern DL, Felton CJ, Hough RL, et al. Housing outcomes for homeless adults with mental illness: results from the second-round McKinney program. Psychiatr Serv. Feb. 1997;48(2):239-41. Epub: 1997/02/01. [pmid: 9021858].
55 Shern DL, Tsemberis S, Anthony W, et al. Serving street-dwelling individuals with psychiatric disabilities: outcomes of a psychiatric rehabilitation clinical trial. Am J Public Health. Dec. 2000;90(12):1873-8. Epub: 2000/12/09. [pmid: 11111259].
56 Hinton DE, Chhean D, Pich V, et al. A randomized controlled trial of cognitive-behavior therapy for Cambodian refugees with treatment-resistant PTSD and panic attacks: a cross-over design. J Trauma Stress. Dec. 2005;18(6):617-29. Epub: 2005/12/31. [pmid: 16382423].
57 Tan G, Teo I, Srivastava D, et al. Improving access to care for women veterans suffering from chronic pain and depression associated with trauma. Pain Med. Jul. 2013;14(7):1010-20. Epub: 2013/05/11. [pmid: 23659470].
58 Druss BG, von Esenwein SA, Compton MT, et al. A randomized trial of medical care management for community mental health settings: the Primary Care Access, Referral, and Evaluation (PCARE) study. Am J Psychiatry. Feb. 2010;167(2):151-9. Epub: 2009/12/17. [pmid: 20008945].
59 Kwong K, Chung H, Cheal K, et al. Depression care management for Chinese Americans in primary care: a feasibility pilot study. Community Ment Health J. Apr. 2013;49(2):157-65. Epub: 2011/10/22. [pmid: 22015960].
60 Bao Y, Alexopoulos GS, Casalino LP, et al. Collaborative depression care management and disparities in depression treatment and outcomes. Arch Gen Psychiatry. Jun. 2011;68(6):627-36. [pmid: 21646579].
61 Alvidrez J, Arean PA, Stewart AL. Psychoeducation to increase psychotherapy entry for older African Americans. Am J Geriatr Psychiatry. Jul. 2005;13(7):554-61. Epub: 2005/07/13. [pmid: 16009731].
62 Chinman MJ, Rosenheck R, Lam JA, et al. Comparing consumer and nonconsumer provided case management services for homeless persons with serious mental illness. J Nerv Ment Dis. Jul. 2000;188(7):446-53. Epub: 2000/08/06. [pmid: 10919704].
63 Ferguson MA. Psych nursing in a shelter for the homeless. Am J Nurs. Aug. 1989;89(8):1060-2. Epub: 1989/08/01. [pmid: 2757087].
64 Horvitz-Lennon M, Zhou D, Normand SL, et al. Racial and ethnic service use disparities among homeless adults with severe mental illnesses receiving ACT. Psychiatr Serv. Jun. 2011;62(6):598-604. Epub: 2011/06/03. [pmid: 21632726].
65 Min SY, Wong YL, Rothbard AB. Outcomes of shelter use among homeless persons with serious mental illness. Psychiatr Serv. Mar. 2004;55(3):284-9. Epub: 2004/03/06. [pmid: 15001729].
66 Herman D, Conover S, Felix A, et al. Critical Time Intervention: an empirically supported model for preventing homelessness in high risk groups. J Prim Prev. Jul. 2007;28(3-4):295-312. Epub: 2007/06/02. [pmid: 17541827].
67 Rosenheck R, Morrissey J, Lam J, et al. Service delivery and community: social capital, service systems integration, and outcomes among homeless persons with severe mental illness. Health Serv Res. Aug. 2001;36(4):691-710. Epub: 2001/08/18. [pmid: 11508635].
68 Weinstein LC, Lanoue MD, Plumb JD, et al. A primary care-public health partnership addressing homelessness, serious mental illness, and health disparities. J Am Board Fam Med. May-Jun. 2013;26(3):279-87. Epub: 2013/05/10. [pmid: 23657696].
69 Randolph F, Blasinsky M, Morrissey JP, et al. Overview of the ACCESS Program. Access to Community Care and Effective Services and Supports. Psychiatr Serv. Aug. 2002;53(8):945-8. Epub: 2002/08/06. [pmid: 12161667].
70 Bartels SJ, Aschbrenner KA, Rolin SA, et al. Activating older adults with serious mental illness for collaborative primary care visits. Psychiatr Rehabil J. Dec. 2013;36(4):278-88. Epub: 2013/11/14. [pmid: 24219769].
71 Mohamed S. Adaptation of intensive mental health intensive case management to rural communities in the Veterans Health Administration. Psychiatr Q. Mar. 2013;84(1):103-14. Epub: 2012/06/26. [pmid: 22729625].
72 Interian A, Lewis-Fernandez R, Dixon LB. Improving treatment engagement of underserved U.S. racial-ethnic groups: a review of recent interventions. Psychiatr Serv. Mar. 1. 2013;64(3):212-22. Epub: 2012/12/04. [pmid: 23203442].
73 Cabassa LJ, Druss B, Wang Y, et al. Collaborative planning approach to inform the implementation of a healthcare manager intervention for Hispanics with serious mental illness: a study protocol. Implement Sci. 2011;6:80. Epub: 2011/07/28. [pmid: 21791070].
74 Baker-Ericzen MJ, Connelly CD, Hazen AL, et al. A collaborative care telemedicine intervention to overcome treatment barriers for Latina women with depression during the perinatal period. Fam Syst Health. Sep. 2012;30(3):224-40. Epub: 2012/06/20. [pmid: 22709321].
75 Hauenstein EJ. Testing innovative nursing care: home intervention with depressed rural women. Issues Ment Health Nurs. Jan-Feb. 1996;17(1):33-50. Epub: 1996/01/01. [pmid: 8682665].
76 Steadman HJ, Cocozza JJ, Dennis DL, et al. Successful program maintenance when federal demonstration dollars stop: the ACCESS program for homeless mentally ill persons. Adm Policy Ment Health. Jul. 2002;29(6):481-93. Epub: 2002/12/10. [pmid: 12469702].
77 Bogner HR, de Vries HF. Integrating type 2 diabetes mellitus and depression treatment among African Americans: a randomized controlled pilot trial. Diabetes Educ. Mar-Apr. 2010;36(2):284-92. Epub: 2009/12/31. [pmid: 20040705].
78 Uebelacker LA, Marootian BA, Tigue P, et al. Telephone depression care management for Latino Medicaid health plan members: a pilot randomized controlled trial. J Nerv Ment Dis. Sep. 2011;199(9):678-83. Epub: 2011/09/01. [pmid: 21878782].
79 Corrigan PW, Pickett S, Batia K, et al. Peer navigators and integrated care to address ethnic health disparities of people with serious mental illness. Soc Work Public Health. 2014;29(6):581-93. [pmid: 25144699].
80 Tondora J, O'Connell M, Miller R, et al. A clinical trial of peer-based culturally responsive person-centered care for psychosis for African Americans and Latinos. Clin Trials. Aug. 2010;7(4):368-79. Epub: 2010/06/24. [pmid: 20571133].
81 Morrissey JP, Calloway MO, Thakur N, et al. Integration of service systems for homeless persons with serious mental illness through the ACCESS program. Access to Community Care and Effective Services and Supports. Psychiatr Serv. Aug. 2002;53(8):949-57. Epub: 2002/08/06. [pmid: 12161668].
82 Schraufnagel TJ, Wagner AW, Miranda J, et al. Treating minority patients with depression and anxiety: what does the evidence tell us?. Gen Hosp Psychiatry. Jan-Feb. 2006;28(1):27-36. Epub: 2005/12/27. [pmid: 16377362].
83 Chrishon K, Anderson D, Arora G, et al. Race and psychiatric diagnostic patterns: understanding the influence of hospital characteristics in the National Hospital Discharge Survey. J Natl Med Assoc. Nov-Dec. 2012;104(11-12):505-9. Epub: 2013/04/09. [pmid: 23560352].
84 Gill KJ, Murphy AA, Zechner MR, et al. Co-Morbid Psychiatric and Medical Disorders: Challenges and Strategies. J Rehabil. 2009;75(3):32-40.
85 Moran M. Board Approves Statement on Role in Reducing Physical Health Disparities. Psychiatr News. September. 2015;50(18).
86 American Psychiatric Association. Position Statement on the Role of Psychiatrists in Reducing Physical Health Disparities in Patients with Mental Illness. American Psychiatric Association. 2015. May. October 26, 2015.
87 Burns MN, Montague E, Mohr DC. Initial design of culturally informed behavioral intervention technologies: developing an mHealth intervention for young sexual minority men with generalized anxiety disorder and major depression. J Med Internet Res. 2013;15(12):e271. Epub: 2013/12/07. [pmid: 24311444].
88 Cunningham M, Zayas LH. Reducing depression in pregnancy: designing multimodal interventions. Soc Work. Apr. 2002;47(2):114-23. Epub: 2002/05/22. [pmid: 12019798].
89 Lewis-Fernandez R, Aggarwal NK, Baarnhielm S, et al. Culture and psychiatric evaluation: operationalizing cultural formulation for DSM-5. Psychiatry. Summer. 2014;77(2):130-54. Epub: 2014/05/29. [pmid: 24865197].
90 Aggarwal NK, Desilva R, Nicasio AV, et al. Does the Cultural Formulation Interview for the fifth revision of the diagnostic and statistical manual of mental disorders (DSM-5) affect medical communication? A qualitative exploratory study from the New York site. 2014/11/06 ed. Personal communications with. 2015.
91 American Psychiatric Association. Diagnostic and statistical manual of mental disorders: DSM-5. Washington, DC. American Psychiatric Association. 2013.
92 Dixon L, Lewis-Fernandez R, Goldman H, et al. Adherence disparities in mental health: opportunities and challenges. J Nerv Ment Dis. Oct. 2011;199(10):815-20. Epub: 2011/10/04. [pmid: 21964279].
93 Walker ER, McGee RE, Druss BG. Mortality in mental disorders and global disease burden implications: a systematic review and meta-analysis. JAMA Psychiatry. 2015:334-41. [pmid: 25671328].