# Methods

Systematic reviews require some certainty about how (1) interventions are defined and operationalized and (2) the body of studies to advance understanding of important issues is assembled and synthesized. Technical Briefs done for the Agency for Healthcare Research and Quality (AHRQ), in contrast, are generally more appropriate for emerging issues about health and health care interventions with major uncertainties about definitional issues and limited or no (published) evidence, precisely because they focus on uncertainties in definition, context, and outcomes. As such, the literature search in a Technical Brief could be considered as comprehensively seeking studies that would address its Guiding Questions (GQs), but not necessarily exhaustive, as one would expect from a systematic review. A Technical Brief does not rate the risk of bias of individual studies, synthesize data on outcomes, or grade the strength of the evidence of the literature. Rather, it provides an overview of key issues related to the intervention, such as current indications, relevant patient populations and groups of interest, outcomes measured, and contextual factors that may affect decisions regarding future interventions. Because Technical Briefs generally focus on interventions with limited published data or few completed studies, the goal is to provide an early and objective description of the state of the science, a potential conceptual framework, and insight on the critical issues that may inform future research.

For the four GQs specified above, we reviewed the published and gray literature, taking into consideration insights from Key Informants (KIs) concerning interventions and available evidence. We targeted our review of the literature to rely on the best and most recent evidence available to support GQ 3 (effectiveness of interventions). For GQ 3, our effectiveness question, we conducted a systematic search of the peer-reviewed and gray literature. We addressed GQs 1 and 2 primarily with information from the peer-reviewed and gray literature about interventions identified for GQ 3, while also considering related articles that supported GQs 1, 2, and 4. Across the GQs, the KI's discussions and peer reviewer input helped us identify additional relevant literature and key researchers. To answer GQs 1 and 2, we also considered articles that may be nonsystematic reviews, published descriptions of intervention protocols, or economic evaluations of interventions. When evidence from empirical studies was available, we first summarize that empirical evidence and then we reviewed findings from additional sources that would provide additional insights or context. Responses to GQ 4 were shaped by the peer-reviewed, published literature, gray literature, and discussions with KIs.

## Literature Review

### Published Literature Search

We systematically searched the published literature for studies to address GQs. An experienced research librarian developed our search strategy (Appendix B). We used the Federal government definition of serious mental illness (SMI) to identify studies of individuals meeting our inclusion criteria, that was included in the 1992 Alcohol, Drug Abuse, and Mental Health Services Administration Reorganization Act (P.L. 102-321). Through this Act, Congress directed the Secretary of Health and Human Services to develop a Federal definition of SMI: “Adults with a serious mental illness are persons: (1) age 18 and over, (2) who currently or at any time during the past year, (3) have a diagnosable mental, behavioral, or emotional disorder of sufficient duration to meet diagnostic criteria specified within the Diagnostic and Statistical Manual of Mental Disorders (DSM)-III-R, (4) that has resulted in functional impairment which substantially interferes with or limits one or more major life activities. All of these disorders have episodic, recurrent, or persistent features; however, they vary in terms of severity and disabling effects.”22

To accommodate the timing of the Alcohol, Drug Abuse, and Mental Health Services Administration Reorganization Act, as well as the Diagnostic and Statistical Manual of Mental Disorders, 3^rd^ Edition (DSM-III) that was released in 1980, we systematically searched the published literature from January 1, 1980, through June 4, 2015. We searched in MEDLINE® via PubMed, the Cochrane Library, PsycINFO, Cumulative Index to Nursing and Allied Health Literature (CINAHL), and ProQuest Psychology Journals.

To capture disparities, we used the MeSH headings of “Cultural Competency,” “Healthcare Disparities,” “Health Status Disparities,” “Minority Groups,” “Sexism,” “Discrimination (Psychology),” “Social Discrimination,” “Ageism,” “Racism,” “Rural Population,” “Socioeconomic Factors,” “Social Class,” “Sexual Behavior,” “Homeless Persons,” “African Americans,” “Homosexuality,” “Transgendered Persons,” “Hispanic Americans,” “Asian Americans,” and “Indians, North American.” We also reviewed the reference lists of relevant papers to identify any relevant citations that our electronic searches might have missed, and we examined any literature (identified by specific citation or author) suggested by KIs. We updated initial literature searches in August, 2015, concurrent with the peer-review process. We considered participants as members of a specific “racial and ethnic minority” group if individual studies defined them as such in describing their study populations.

### Gray Literature Search

We searched the gray literature to identify information beyond what would be available the published literature on interventions to reduce disparities among groups of people with SMI. Sources for the gray literature included the following: OpenSIGLE, ClinicalTrials.gov, Academic Search Premier, and NIH RePORTER. We also searched Web sites of the National Guidelines Clearinghouse, the National Quality Measures Clearinghouse, and The Joint Commission. Appendix C briefly describes each of these gray literature sources.

## Eligibility Criteria

We carefully considered how best to define our eligibility criteria to reflect the current state of the science describing interventions for reducing disparities in mental health care (GQs 1, 2, and 4) and to examine the current evidence base for the effectiveness of these interventions (GQ 3). We aimed to be more inclusive of individuals who would be considered as having SMI. Because of its breadth and to promote consistency in this research area, we used the previously published definition of SMI included in the AHRQ EPC technical brief concerning the measure development in serious mental illness.1

### SMI Diagnosis

Our basic population of interest was adults (≥18 years of age) with SMI currently or at any time during the past year. Based on the Federal definition of SMI stated above and on the request of the topic nominator, we defined SMI to include a clinical diagnosis of (1) schizophrenia or schizoaffective disorder (or other related primary psychotic disorder), (2) bipolar disorder, (3) current major depressive disorder, (4) anxiety disorders, (5) eating disorders, or (6) personality disorders. The diagnoses should relate to the Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition (DSM-IV) or the International Classification of Diseases, Ninth Revision, Clinical Modification (ICD-9-CM) equivalent (and subsequent revisions). We also included a clinical diagnoses of dysthymia among the SMI-eligible diagnoses to accommodate studies with mixed populations of individuals with major depressive disorder, dysthymia, or a combination of both diagnoses. Dysthymia can sometimes involve functional impairment that substantially interferes with or limits one or more major life activities, a key feature of SMI.

### Disparity Groups

Given that many groups of people with SMI experience disparities in health care and outcomes, we focused this Technical Brief on particular groups of concern suggested by the nominator (and confirmed by the KIs) appearing in the available literature. Adults with SMI had to be a part of a group identified as being at risk of experiencing a mental health care disparity based on one or more of the following attributes: minority race or ethnicity; gender; low socioeconomic status (including homelessness); age (being elderly); geographic location (residing in a rural area); identifying as lesbian, gay, bisexual, and/or transgender (LGBT); or having difficulties communicating in English (English as a second language).

For studies included in this report, terminology used to refer to individuals identifying as LGBT and the various racial and ethnic groups is consistent with the source publication whenever possible.

The literature commonly identified homeless individuals by self-reports of living on the streets or in a homeless or similar type of shelter or temporary accommodations for a specific amount of time. Some studies specifically used the definition from the National Institute of Mental Health23 to define their homeless populations. We also considered these study populations as homeless.

We initially considered the elderly population to be 65 years of age or older, but because we found a paucity of studies meeting this restriction, we also considered studies as focusing on the elderly if the majority of individuals were within the specified age range and investigators considered their study populations as elderly.

### Interventions

We included interventions intended to reduce various disparities in care and outcomes of care among these groups of adults with SMI by, at the least, focusing on specific disparity group patients. Health outcomes included, but were not limited to, the following: mental health outcomes, housing stability among the homeless group, physical health outcomes, quality of life, and satisfaction with care. To help ensure that we evaluated health care disparities at all points along the health care continuum, we broadly included articles in which the setting was inpatient or outpatient and in which clinicians and support staff provided primary care, mental health (specialty) care, or both. We excluded articles about studies conducted outside the United States or not published in English to maximize the likelihood of generalizability to our topic nominators' populations of interest and relevant treatment settings.

## Study Design

We developed slightly different criteria for our two sets of questions: GQs 1, 2, and 4 as one set and GQ 3 as the other. For GQs 1, 2, and 4, to ensure that we captured the spectrum of current thinking and evidence on reducing disparities, we applied no study design restrictions. We anticipated that relevant information might come from a variety of publications, including review articles, qualitative research, feasibility studies, study protocols, and opinion pieces. We did not require articles to report on outcomes for these GQs.

For GQ 3, we applied stricter criteria for our review of the evidence on the effectiveness of interventions to reduce health care disparities. Articles were required to report on outcomes related to interventions to reduce health care disparities. We excluded articles if the study designs were case reports or case series; cross-sectional studies; nonsystematic reviews; or commentaries, opinions, or letters to the editor with no primary data.

### Literature Dual Review Process

Trained members of the research team dually reviewed all abstracts for eligibility based on the preestablished inclusion/exclusion criteria presented in Table 1. Inclusion/exclusion criteria are organized in terms of PICOTS (populations, interventions, comparators, outcomes, time frames, and settings) as well as study design, language, and publication date. Any study with inadequate information in the abstract or marked for possible inclusion by at least one reviewer underwent full-text review. We retrieved and dually reviewed the full text of all articles included during the title/abstract review phase. Trained members of the research team dually reviewed each full-text article for inclusion or exclusion on the basis of the eligibility criteria presented in Table 1. Reasons for exclusion were documented and articles marked for inclusion were tagged for the relevant GQ(s) that the article addressed. Disagreements about inclusion (i.e., one reviewer included and one reviewer excluded the article) were resolved by discussion or consensus with review by the research team as needed.

Table 1 Selection criteria for relevant interventions to reduce disparities for groups of patients with SMI^a^

Criterion | Inclusion | Exclusion
Population | All GQs ≥18 years with SMI currently or at any time during the past year AND Part of a group identified as being at risk of experiencing a mental health care disparity based on minority race or ethnicity, gender, low socioeconomic status (including homelessness), geographic location (rural residence), identifying as LGBT, being elderly, or difficulty communicating in the local primary language (e.g., English as a second language) | All GQs <18 years Primary diagnosis of substance abuse, dementia, or mental retardation
Intervention | All GQs Interventions intended to reduce disparities among groups of individuals with SMI, including disparities in (1) access to accurate diagnostic evaluation; (2) access to health care, including health care coverage; (3) quality of health care; or (4) adherence to treatment, response to treatment, or health outcomes | All GQs Approaches that do not attempt to reduce these disparities
Comparator | GQs 1, 2, and 4 No limitations GQ 3 Another intervention to reduce the same disparity in the same outcome(s) Usual care/active control Waitlist/placebo No comparator for single group pre-post studies | GQs 1, 2, and 4 Not applicable GQ 3 Studies with no comparator group except for single group pre-post studies
Outcomes | GQs 1, 2, and 4 No limitations GQ 3 Benefits, including improvements among disparity group members in (1) access to health insurance with appropriate coverage for these conditions; (2) access to accurate diagnostic evaluations; (3) access to necessary and appropriate therapeutic services; (4) quality of health services received; (5) adherence to treatment; and (6) other outcomes of care, which can include, but would not be limited to: remission of disorder, symptom relapse, physical health and functioning, broader quality of life domains (including housing stability), and satisfaction with care. Harms or adverse effects of using these interventions | GQs 1, 2, and 4 Not applicable GQ 3 Outcomes not attributable to the interventions of interest
Time frames | All GQs No limitations | All GQs None
Setting | All GQs Inpatient or outpatient Primary care or mental health (specialty) care United States | All GQs No setting described in the study Non-United States
Study design | GQs 1, 2, and 4 No limitations GQ 3 Systematic reviews Randomized controlled trials Nonrandomized controlled trials Prospective and retrospective cohort studies Case-control studies Single-group pre-post studies | GQs 1, 2, and 4 None GQ 3 Case reports Case series Cross-sectional studies Opinions Commentaries Nonsystematic reviews Letters to the editor with no primary data
Other | All GQs English language Published 1980 and later | All GQs Non-English language Published prior to 1980

a SMI defined as (1) schizophrenia or schizoaffective disorder (or other related primary psychotic disorder), (2) bipolar disorder, (3) depression, (4) anxiety disorders, (5) eating disorders, or (6) personality disorders, per DSM-IV (Diagnostic and Statistical Manual of Mental Disorders, 4^th^ Edition) or their ICD-9-CM (International Classification of Diseases, Ninth Revision, Clinical Modification) equivalent (and subsequent revisions).

GQ = Guiding Question; LGBT = lesbian, gay, bisexual, transgender; SMI = serious mental illness.

## Discussions With KIs

KIs provide context to empirical findings (or lack of them) and may raise new concerns that prompt additional literature searches. KIs were particularly vital to shaping this Technical Brief because of their contributions to the myriad conceptual frameworks related to interventions for reducing health care disparities among SMI groups. Distinguishing commonalities or differences in how studies defined disparities or SMI (or both) was expected to be particularly challenging.

In consultation with our team and AHRQ staff, we identified distinct perspectives that we needed to develop a well-rounded and balanced Technical Brief on interventions for reducing health care disparities among groups of people with SMI. Specifically, we recruited six KIs representing a spectrum of expertise and stakeholder interests: mental health providers and representatives of professional societies (four KIs), patient advocacy groups (one KI), and Federal policymakers (one KI). Some KIs represented multiple fields of expertise and provided insights into the issues the SMI population faces. More detail about the KI process is available in Appendix D.

We interviewed KIs through telephone calls, having shared our preliminary GQs and other materials with them before the calls. An experienced moderator led the calls following a semistructured guide with built-in places for obtaining input from the KIs. We used insights from KIs to confirm the findings from our literature review and the scope of our eventual Technical Brief. We began each KI interview with introductory questions that addressed definitional aspects of this Technical Brief, namely how the KI would define “disparities” and “usual care” for disparate groups. We asked the KIs what the important disparate groups were within a broader SMI patient population. Following that discussion, we focused on the preliminary GQs related to interventions to reduce disparities among the groups of interest, using the subquestions for each GQ as prompts to discuss issues further.

## Data Management and Abstraction

We collected information from discussions with KIs, comprehensive searches of the peer-reviewed literature, and targeted searches of the gray literature. All literature screening results were tracked in an EndNote database. We recorded the reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix E). We abstracted data from each study that met our inclusion criteria for GQ 3, using a standardized template. One member of the review team recorded the data, and a second team member reviewed those data in the template for accuracy and completeness. The following information was obtained from each study, where applicable: author, year of publication, source of study funding, study design characteristics, study population (including study inclusion and exclusion criteria), the group(s) of interest, the primary SMI diagnosis, interventions to reduce disparities, duration of patient followup, outcomes assessed (specific measures used and timing of assessment), and other pertinent information.

## Peer Review and Public Comment

The draft Technical Brief was available for peer review and public comment at www.effectivehealthcare.ahrq.gov from July 31 to September 8, 2015. Six peer reviewers provided feedback on the draft; no individuals or organizations offered public comment. We revised the Brief in response to these comments where appropriate.