# Guiding Questions

Technical Briefs are structured in terms of “guiding questions” (GQs) of interest to groups that nominate the topic to the Agency for Healthcare Research and Quality (AHRQ). They may be explored or refined in various ways (e.g., by interviews with representatives of critical stakeholder groups or formal procedures for exploring significant clinical or policy issues through panels and forums). The original GQs posed for this Technical Brief are in Appendix A.

The four refined GQs for this Technical Brief that are listed below focus on the critical areas of concern in relation to disparities—access to health insurance with appropriate coverage for these serious mental health (SMI) conditions, accurate diagnostic evaluations, receipt of necessary and appropriate therapeutic services, quality of the health services provided and received, adherence to treatment over the long term, and various outcomes of care. The principal focus for the first three GQs is a description of the interventions and the context in which they are implemented and tested (GQs 1 and 2), as well as a description of the evidence about the effectiveness of the interventions (GQ 3); GQ 4 examines the gaps in the knowledge base and the high-priority needs for future research.

The specific issues for the four GQs are the following:

1. From available evidence and input from Key Informants (KIs): Describe interventions (types or modalities) to reduce disparities among SMI groups. Interventions may address one or more of the concerns stated above. Primary subquestions include:
  a. What are the goals, components, and outcomes of the interventions?
  b. What are the disparity subgroups that are the focus of the interventions?
  c. What are the potential advantages and disadvantages of these types of interventions?
2. From available evidence and input from KIs: Describe the context for each intervention (type or modality) identified in GQ 1 to reduce disparities among SMI groups. Key contextual subquestions concern the following:
  a. What is the setting for the intervention?
  b. What responsibilities do the health professionals (including clinicians) participating in the intervention have for the medical and mental health care of patients with SMI?
  c. What resources (e.g., health information technology) are needed to provide the intervention?
3. From available evidence: Describe the current evidence about the effectiveness (or comparative effectiveness) of interventions that have been implemented to reduce disparities among SMI groups. Interventions may address one or more of any of the concerns identified for GQs 1 and 2. Data on a specific intervention will include but not be limited to:
  a. patient inclusion criteria;
  b. type of intervention and setting;
  c. comparator intervention(s) used in comparative effectiveness evaluations, if any; and
  d. outcomes.
4. From available evidence and input from KIs, identify gaps in knowledge and future research needs, with specific attention to the following subquestions:
  a. Are any interventions to address disparities among SMI groups planned by researchers, clinicians, patient advocacy groups, or others, but not yet implemented?
  b. In current interventions, are the correct outcomes being measured? Are relevant outcomes being measured with appropriate instruments and data?
  c. What gaps exist in the evidence base for best practices or interventions for addressing disparities in SMI?
  d. What are possible areas of future research? What are potential long-term (10 years or more) developments in this field?