# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Andrea Ault-Brutus, Ph.D.
  Center for Multicultural Mental Health Research
  Cambridge Health Alliance
  Somerville, MA
- Charlene Le Fauve, Ph.D.
  Deputy Director
  Office for Research on Disparities & Global Mental Health
  National Institute of Mental Health
  National Institutes of Health
  Department of Health and Human Services
  Bethesda, MD
- Annelle Primm, M.D., M.P.H.
  American Psychiatric Association (APA)
  Baltimore, MD
- Sharon R. Yates
  Yates Management Consultancy
  Los Angeles, CA