# Key Informants

In designing the study questions, the EPC consulted a panel of Key Informants who represent subject experts and end-users of research. Key Informant input can inform key issues related to the topic of the technical brief. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Stephen Bartels, M.D., M.S.
  Departments of (a) Psychiatry, (b) Community & Family Medicine, (c) The Dartmouth Institute of Health Policy and Clinical Practice, and (d) Dartmouth Centers for Health and Aging, Geisel School of Medicine at Dartmouth College
  Lebanon, NH
- MaJose Carrasco, M.P.A.^*^
  * The Key Informant also provided review of the draft report.
  Multicultural Action Center (MAC), National Alliance on Mental Illness
  Arlington, VA
- Judith Hirsh, F.P.M.H.N.P, P.M.H.C.N.S.-B.C.
  Yavapai County Community Health Services
  Phoenix, AZ
- Roberto Lewis-Fernandez, M.D., M.T.S.^*^
  Psychiatry, Columbia University Med. Center
  New York, NY
  Global Health and Social Medicine, Harvard University
  Boston, MA
- Madeleine Shea, Ph.D.
  Office of Minority Health, Centers for Medicare & Medicaid Services, Department of Health and Human Services
  Baltimore, MD
- Marvin Swartz, M.D., M.P.H.
  Duke Psychiatry and Behavioral Sciences, Duke University School of Medicine
  Durham, NC