# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Elise Berliner, Ph.D. We thank our Associate Editor, Mary Butler, Ph.D., for helpful comments on a draft version of the report.

The authors deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at the RTI International–University of North Carolina EPC. We express our gratitude to the following individuals for their contributions to this project: Lynn Whitener, Dr.P.H., M.S.L.S., Librarian; Sharon Barrell, M.A., editor, and Loraine Monroe, publications specialist.