# Excluded Studies

Exclusion Codes:

- X0-Irretrievable publication
- X1-Ineligible publication type: Not published in English
- X2-Ineligible publication: Published prior to 1980
- X3-Ineligible setting: Non-US
- X4-Ineligible setting: Not inpatient or outpatient, primary care or mental health care setting
- X5-Ineligible population: Too young, all participants are <18 years of age
- X6-Ineligible population: Does not focus on individuals with SMI now or in the past year
- X7-Ineligible population: Does not focus on a disparity group with SMI
- X8-Ineligible intervention: No intervention(s)
- X9-Ineligible comparator: Ineligible or no comparator(s)
- X10-Ineligible outcome: Ineligible or no outcome(s)

1 Adams CE, Rash CJ, Burke RS, et al. Contingency Management for Patients with Cooccurring Disorders: Evaluation of a Case Study and Recommendations for Practitioners. Case Reports in Psychiatry. 2012:1-7. Exclusion Code: X6.
2 Aggarwal NK, Desilva R, Nicasio AV, et al. Does the Cultural Formulation Interview for the fifth revision of the diagnostic and statistical manual of mental disorders (DSM-5) affect medical communication? A qualitative exploratory study from the New York site. Ethn Health. 2014/11/06 ed. 2015:1-28. Exclusion Code: X6.
3 Aggarwal NK, Nicasio AV, DeSilva R, et al. Barriers to implementing the DSM-5 cultural formulation interview: a qualitative study. Cult Med Psychiatry. Sep. 2013;37(3):505-33. Exclusion Code: X6. [pmid: 23836098].
4 Aguilar-Gaxiola SA, Zelezny L, Garcia B, et al. Translating research into action: reducing disparities in mental health care for Mexican Americans. Psychiatr Serv. Dec. 2002;53(12):1563-8. Exclusion Code: X8. [pmid: 12461216].
5 Alegria M, Carson N, Flores M, et al. Activation, self-management, engagement, and retention in behavioral health care: a randomized clinical trial of the DECIDE intervention. JAMA Psychiatry. May. 2014;71(5):557-65. Exclusion Code: X6. [pmid: 24647680].
6 Alegria M, Polo A, Gao S, et al. Evaluation of a patient activation and empowerment intervention in mental health care. Med Care. Mar. 2008;46(3):247-56. Exclusion Code: X6. [pmid: 18388839].
7 Alexander MJ, Haugland G, Ashenden P, et al. Coping with thoughts of suicide: Techniques used by consumers of mental health services. Psychiatr Serv. 2009;60(9):1214-21. Exclusion Code: X7. [pmid: 19723736].
8 Alvidrez J, Arean PA, Stewart AL. Psychoeducation to increase psychotherapy entry for older African Americans. Am J Geriatr Psychiatry. Jul. 2005;13(7):554-61. Exclusion Code: X6. [pmid: 16009731].
9 Amirkhanian YA, Kelly JA, McAuliffe TL. Psychosocial needs, mental health, and HIV transmission risk behavior among people living with HIV/AIDS in St Petersburg, Russia. AIDS. Nov. 7. 2003;17(16):2367-74. Exclusion Code: X3. [pmid: 14571189].
10 Arnold JG, Miller AL, Canive JM, et al. Comparison of outcomes for African Americans, Hispanics, and Non-Hispanic Whites in the CATIE study. Psychiatr Serv. Jun. 2013;64(6):570-8. Exclusion Code: X8. [pmid: 23494108].
11 Aviera A. “Dichos” therapy group: a therapeutic use of Spanish language proverbs with hospitalized Spanish-speaking psychiatric patients. Cult Divers Ment Health. 1996;2(2):73-87. Exclusion Code: X9. [pmid: 9225563].
12 Baker-Ericzen MJ, Connelly CD, Hazen AL, et al. A collaborative care telemedicine intervention to overcome treatment barriers for Latina women with depression during the perinatal period. Fam Syst Health. Sep. 2012;30(3):224-40. Exclusion Code: X6. [pmid: 22709321].
13 Balan IC, Moyers TB, Lewis-Fernandez R. Motivational pharmacotherapy: combining motivational interviewing and antidepressant therapy to improve treatment adherence. Psychiatry. Fall. 2013;76(3):203-9. Exclusion Code: X6. [pmid: 23965260].
14 Bao Y, Alexopoulos GS, Casalino LP, et al. Collaborative depression care management and disparities in depression treatment and outcomes. Arch Gen Psychiatry. Jun. 2011;68(6):627-36. Exclusion Code: X6. [pmid: 21646579].
15 Bartels SJ. Commentary: the forgotten older adult with serious mental illness: the final challenge in achieving the promise of Olmstead?. J Aging Soc Policy. Jul-Sep. 2011;23(3):244-57. Exclusion Code: X9. [pmid: 21740200].
16 Bartels SJ. Can behavioral health organizations change health behaviors? The STRIDE study and lifestyle interventions for obesity in serious mental illness. The American Journal of Psychiatry. 2015;172(1):9-11. Exclusion Code: X7. [pmid: 25553493].
17 Bartels SJ, Aschbrenner KA, Rolin SA, et al. Activating older adults with serious mental illness for collaborative primary care visits. Psychiatr Rehabil J. Dec. 2013;36(4):278-88. Exclusion Code: X9. [pmid: 24219769].
18 Bartels SJ, Naslund JA. The underside of the silver tsunami--older adults and mental health care. N Engl J Med. Feb. 7. 2013;368(6):493-6. Exclusion Code: X8. [pmid: 23343039].
19 Bartels SJ, Pepin R, Gill LE. The Paradox of Scarcity in a Land of Plenty: Meeting the Needs of Older Adults with Mental Health and Substance Use Disorders. Generations. Fall. 2014;38(3):6-13. Exclusion Code: X8. [pmid: 25663741].
20 Bartels SJ, Pratt SI, Mueser KT, et al. Long-term outcomes of a randomized trial of integrated skills training and preventive healthcare for older adults with serious mental illness. Am J Geriatr Psychiatry. Nov. 2014;22(11):1251-61. Exclusion Code: X7. [pmid: 23954039].
21 Bartels SJ, Pratt SI, Mueser KT, et al. Integrated IMR for psychiatric and general medical illness for adults aged 50 or older with serious mental illness. Psychiatr Serv. Mar. 1. 2014;65(3):330-7. Exclusion Code: X7. [pmid: 24292559].
22 Baumgartner JN, Herman DB. Community integration of formerly homeless men and women with severe mental illness after hospital discharge. Psychiatr Serv. 2012;63(5):435-7. Exclusion Code: X7. [pmid: 22549529].
23 Bayard-Cooks R. Momma's story: An exploratory case study of Black mothers' experiences caring for a son with a severe mental illness and history of incarceration. US. ProQuest Information & Learning. 2012. Exclusion Code: X0.
24 Beach SR, Brody GH, Kogan SM, et al. Change in caregiver depression in response to parent training: genetic moderation of intervention effects. J Fam Psychol. Feb. 2009;23(1):112-7. Exclusion Code: X5. [pmid: 19203166].
25 Beeber LS. A clinical translation of the research article titled, ‘exploring the impact of race on mental health service utilization among African Americans and whites with severe mental illness’. J Am Psychiatr Nurses Assoc. 2010;16(2):90-2. Exclusion Code: X8. [pmid: 21659265].
26 Beeber LS, Cooper C, Van Noy BE, et al. Flying under the radar: engagement and retention of depressed low-income mothers in a mental health intervention. ANS Adv Nurs Sci. Jul-Sep. 2007;30(3):221-34. Exclusion Code: X6. [pmid: 17703122].
27 Beeber LS, Holditch-Davis D, Belyea MJ, et al. In-home intervention for depressive symptoms with low-income mothers of infants and toddlers in the United States. Health Care Women Int. Jun-Jul. 2004;25(6):561-80. Exclusion Code: X6. [pmid: 15354622].
28 Belcher JR. Defining the service needs of homeless mentally ill persons. Hosp Community Psychiatry. Nov. 1988;39(11):1203-5. Exclusion Code: X8. [pmid: 3224957].
29 Belcher JR. The homeless mentally ill and the need for a total care environment. Can J Psychiatry. Apr. 1989;34(3):186-9. Exclusion Code: X8. [pmid: 2720551].
30 Bell MD, Lysaker PH. Clinical benefits of paid work activity in schizophrenia: 1-year followup. Schizophr Bull. 1997;23(2):317-28. Exclusion Code: X7. [pmid: 9165640].
31 Bluthenthal RN, Jones L, Fackler-Lowrie N, et al. Witness for Wellness: preliminary findings from a community-academic participatory research mental health initiative. Ethn Dis. Winter. 2006;16(1 Suppl 1):S18-34. Exclusion Code: X4. [pmid: 16681126].
32 Bogner HR, de Vries HF. Integrating type 2 diabetes mellitus and depression treatment among African Americans: a randomized controlled pilot trial. Diabetes Educ. Mar-Apr. 2010;36(2):284-92. Exclusion Code: X6. [pmid: 20040705].
33 Bond GR, Becker DR, Drake RE, et al. Implementing supported employment as an evidence-based practice. Psychiatr Serv. Mar. 2001;52(3):313-22. Exclusion Code: X8. [pmid: 11239097].
34 Breland-Noble AM. Community and treatment engagement for depressed African American youth: the AAKOMA FLOA pilot. J Clin Psychol Med Settings. Mar. 2012;19(1):41-8. Exclusion Code: X5. [pmid: 22354616].
35 Breland-Noble AM, Bell C, Nicolas G. Family first: the development of an evidence-based family intervention for increasing participation in psychiatric clinical care and research in depressed African American adolescents. Fam Process. Jun. 2006;45(2):153-69. Exclusion Code: X5. [pmid: 16768016].
36 Burns MN, Montague E, Mohr DC. Initial design of culturally informed behavioral intervention technologies: developing an mHealth intervention for young sexual minority men with generalized anxiety disorder and major depression. J Med Internet Res. 2013;15(12):e271. Exclusion Code: X4. [pmid: 24311444].
37 Burt MR, Pearson C, Montgomery AE. Community-wide strategies for preventing homelessness: recent evidence. J Prim Prev. Jul. 2007;28(3-4):213-28. Exclusion Code: X7. [pmid: 17558555].
38 Cabassa LJ, Druss B, Wang Y, et al. Collaborative planning approach to inform the implementation of a healthcare manager intervention for Hispanics with serious mental illness: a study protocol. Implement Sci. 2011;6:80. Exclusion Code: X4. [pmid: 21791070].
39 Cabassa LJ, Hansen MC, Palinkas LA, et al. Azucar y nervios: explanatory models and treatment experiences of Hispanics with diabetes and depression. Soc Sci Med. Jun. 2008;66(12):2413-24. Exclusion Code: X6. [pmid: 18339466].
40 Calsyn RJ. A modified ESID approach to studying mental illness and homelessness. Am J Community Psychol. Dec. 2003;32(3-4):319-31. Exclusion Code: X4. [pmid: 14703267].
41 Campbell K, Bond GR, Drake RE. Who benefits from supported employment: a meta-analytic study. Schizophr Bull. Mar. 2011;37(2):370-80. Exclusion Code: X7. [pmid: 19661196].
42 Carpenter-Song E, Whitley R, Lawson W, et al. Reducing disparities in mental health care: suggestions from the Dartmouth-Howard collaboration. Community Ment Health J. 2011;47(1):1-13. Language: English. Entry Date: 20110304. Revision Date: 20120210. Publication Type: journal article. Journal Subset: Biomedical. Exclusion Code: X8. [pmid: 19662528].
43 Casas RN, Gonzales E, Aldana-Aragón E, et al. Toward the early recognition of psychosis among Spanish-speaking adults on both sides of the U.S.–Mexico border. Psychol Serv. 2014;11(4):460-9. Exclusion Code: X6. [pmid: 25383998].
44 Cassells A, Lin TJ. Collaborative Care to Reduce Depression and Increase Cancer Screening Among Low-Income Urban Women Project (Prevention Care Manager 3 Project) (PCM3). Clinical Directors Network. Bronx, New York. ClinicalTrials.gov. October. 17. 2014. 2014. Exclusion Code: X0.
45 Chen FP, Ogden L. A working relationship model that reduces homelessness among people with mental illness. Qual Health Res. Mar. 2012;22(3):373-83. Exclusion Code: X8. [pmid: 21890715].
46 Chesney MA, Chambers DB, Taylor JM, et al. Coping effectiveness training for men living with HIV: results from a randomized clinical trial testing a group-based intervention. Psychosom Med. Nov-Dec. 2003;65(6):1038-46. Exclusion Code: X6. [pmid: 14645783].
47 Chinman MJ, Rosenheck R, Lam JA, et al. Comparing consumer and nonconsumer provided case management services for homeless persons with serious mental illness. J Nerv Ment Dis. Jul. 2000;188(7):446-53. Exclusion Code: X9. [pmid: 10919704].
48 Cocozza JJ, Steadman HJ, Dennis DL, et al. Successful systems integration strategies: the access program for persons who are homeless and mentally ill. Adm Policy Ment Health. Jul. 2000;27(6):395-407. Exclusion Code: X9. [pmid: 11077703].
49 Cole S, Reims K, Kershner L, et al. Improving care for depression: performance measures, outcomes and insights from the Health Disparities Collaboratives. J Health Care Poor Underserved. Aug. 2012;23(3 Suppl):154-73. Exclusion Code: X7. [pmid: 22864495].
50 Collado A, Long KE, MacPherson L, et al. The efficacy of a behavioral activation intervention among depressed US Latinos with limited English language proficiency: study protocol for a randomized controlled trial. Trials. 2014;15:231. Exclusion Code: X10. [pmid: 24938081].
51 Collins PY, Geller PA, Miller S, et al. Ourselves, our bodies, our realities: an HIV prevention intervention for women with severe mental illness. J Urban Health. Mar. 2001;78(1):162-75. Exclusion Code: X7. [pmid: 11368195].
52 Cook BL, Doksum T, Chen CN, et al. The role of provider supply and organization in reducing racial/ethnic disparities in mental health care in the U.S. Soc Sci Med. May. 2013;84:102-9. Exclusion Code: X6. [pmid: 23466259].
53 Correll JA, Cantrell P, Dalton WT. Integration of behavioral health services in a primary care clinic serving rural Appalachia: reflections on a clinical experience. Fam Syst Health. Dec. 2011;29(4):291-302. Exclusion Code: X6. [pmid: 22214296].
54 Corrigan P. Integrated Care & Patient Navigators for Latinos With Serious Mental Illness. Illinois Institute of Technology. Chicago. 2015. https://www.clinicaltrials.gov/ct2/show/NCT02469714. Exclusion Code: X9.
55 Corrigan PW, Morris SB, Michaels PJ, et al. Challenging the public stigma of mental illness: A meta-analysis of outcome studies. Psychiatr Serv. 2012;63(10):963-73. Exclusion Code: X6. [pmid: 23032675].
56 Corrigan PW, Pickett S, Batia K, et al. Peer navigators and integrated care to address ethnic health disparities of people with serious mental illness. Soc Work Public Health. 2014;29(6):581-93. Exclusion Code: X9. [pmid: 25144699].
57 Costantino G, Malgady RG, Primavera LH. Congruence between culturally competent treatment and cultural needs of older Latinos. J Consult Clin Psychol. Oct. 2009;77(5):941-9. Exclusion Code: X9. [pmid: 19803573].
58 Crockett K, Zlotnick C, Davis M, et al. A depression preventive intervention for rural low-income African-American pregnant women at risk for postpartum depression. Arch Womens Ment Health. Dec. 2008;11(5-6):319-25. Exclusion Code: X6. [pmid: 18982408].
59 Cully JA, Breland JY, Robertson S, et al. Behavioral health coaching for rural veterans with diabetes and depression: a patient randomized effectiveness implementation trial. BMC Health Serv Res. 2014;14:191. Exclusion Code: X6. [pmid: 24774351].
60 Daub S. Turning toward treating the seriously mentally ill in primary care. Families, Systems, & Health. 2014;32(1):12-3. Exclusion Code: X7.
61 Davis TD, Deen T, Bryant-Bedell K, et al. Does minority racial-ethnic status moderate outcomes of collaborative care for depression?. Psychiatr Serv. Nov. 2011;62(11):1282-8. Exclusion Code: X6. [pmid: 22211206].
62 DeCoux Hampton M. The role of treatment setting and high acuity in the overdiagnosis of schizophrenia in African Americans. Arch Psychiatr Nurs. 2007;21(6):327-35. Exclusion Code: X8. [pmid: 18037443].
63 DeCoux Hampton M, Chafetz L, White MC. Exploring the Impact of Race on Mental Health Service Utilization Among African Americans and Whites With Severe Mental Illness. J Am Psychiatr Nurses Assoc. May. 2010. 2010;16(2):78-88. 12686318. Exclusion Code: X8. [pmid: 21659264].
64 Denkins BA. Are we really helping? The problem of dual diagnoses, homelessness, & hospital-hopping. J Psychosoc Nurs Ment Health Serv. Nov. 2005;43(11):48-50. Exclusion Code: X8. [pmid: 16350915].
65 Desai MM, Rosenheck RA. Unmet need for medical care among homeless adults with serious mental illness. Gen Hosp Psychiatry. Nov-Dec. 2005;27(6):418-25. Exclusion Code: X8. [pmid: 16271656].
66 Dinh TQT. Sociocultural influences on mental health functioning over time: Implications for the design of community-based services. US. ProQuest Information & Learning. 2009. Exclusion Code: X0.
67 Dixon L, Lewis-Fernandez R, Goldman H, et al. Adherence disparities in mental health: opportunities and challenges. J Nerv Ment Dis. Oct. 2011;199(10):815-20. Exclusion Code: X6. [pmid: 21964279].
68 Dobransky-Fasiska D, Brown C, Pincus HA, et al. Developing a community-academic partnership to improve recognition and treatment of depression in underserved African American and white elders. Am J Geriatr Psychiatry. Nov. 2009;17(11):953-64. Exclusion Code: X6. [pmid: 20104053].
69 Dobransky-Fasiska D, Nowalk MP, Cruz M, et al. A community-academic partnership develops a more responsive model to providing depression care to disadvantaged adults in the US. Int J Soc Psychiatry. May. 2012;58(3):295-305. Exclusion Code: X6. [pmid: 21441280].
70 Dobransky-Fasiska D, Nowalk MP, Pincus HA, et al. Public-academic partnerships: improving depression care for disadvantaged adults by partnering with non-mental health agencies. Psychiatr Serv. Feb. 2010;61(2):110-2. Exclusion Code: X6. [pmid: 20123813].
71 Downing DA. Response to “Flying under the RADAR: engagement and retention of depressed low-income mothers in a mental health intervention”. ANS Adv Nurs Sci. Jan-Mar. 2008;31(1):2-3. Exclusion Code: X6. [pmid: 20531264].
72 Dwight-Johnson M, Aisenberg E, Golinelli D, et al. Telephone-based cognitive-behavioral therapy for Latino patients living in rural areas: a randomized pilot study. Psychiatr Serv. Aug. 2011;62(8):936-42. Exclusion Code: X6. [pmid: 21807834].
73 Dwight-Johnson M, Ell K, Lee PJ. Can collaborative care address the needs of low-income Latinas with comorbid depression and cancer? Results from a randomized pilot study. Psychosomatics. May-Jun. 2005;46(3):224-32. Exclusion Code: X6. [pmid: 15883143].
74 Dwight-Johnson M, Lagomasino IT, Hay J, et al. Effectiveness of collaborative care in addressing depression treatment preferences among low-income Latinos. Psychiatr Serv. Nov. 2010;61(11):1112-8. Exclusion Code: X6. [pmid: 21041350].
75 Eack SM, Bahorik AL, Newhill CE, et al. Interviewer-perceived honesty as a mediator of racial disparities in the diagnosis of schizophrenia. Psychiatr Serv. 2012;63(9):875-80. Exclusion Code: X8. [pmid: 22751938].
76 Edwards VR. Clinical case management with severely mentally ill African Americans. Manoleas P, editor. The cross-cultural practice of clinical case management in mental health. New York, NY, England. Haworth Press, Inc. 1996:169-84. Exclusion Code: X9.
77 Ell K, Aranda MP, Xie B, et al. Collaborative depression treatment in older and younger adults with physical illness: pooled comparative analysis of three randomized clinical trials. Am J Geriatr Psychiatry. Jun. 2010;18(6):520-30. Exclusion Code: X6. [pmid: 20220588].
78 Ell K, Katon W, Cabassa LJ, et al. Depression and diabetes among low-income Hispanics: design elements of a socioculturally adapted collaborative care model randomized controlled trial. Int J Psychiatry Med. 2009;39(2):113-32. Exclusion Code: X6. [pmid: 19860071].
79 Ell K, Katon W, Xie B, et al. Collaborative care management of major depression among low-income, predominantly Hispanic subjects with diabetes: a randomized controlled trial. Diabetes Care. Apr. 2010;33(4):706-13. Exclusion Code: X6. [pmid: 20097780].
80 Ell K, Quon B, Quinn DI, et al. Improving treatment of depression among low-income patients with cancer: the design of the ADAPt-C study. Gen Hosp Psychiatry. May-Jun. 2007;29(3):223-31. Exclusion Code: X6. [pmid: 17484939].
81 Ell K, Xie B, Kapetanovic S, et al. One-year follow-up of collaborative depression care for low-income, predominantly Hispanic patients with cancer. Psychiatr Serv. Feb. 2011;62(2):162-70. Exclusion Code: X6. [pmid: 21285094].
82 Ell K, Xie B, Quon B, et al. Randomized controlled trial of collaborative care management of depression among low-income patients with cancer. J Clin Oncol. Sep. 20. 2008;26(27):4488-96. Exclusion Code: X6. [pmid: 18802161].
83 Ferguson MA. Psych nursing in a shelter for the homeless. Am J Nurs. Aug. 1989;89(8):1060-2. Exclusion Code: X9. [pmid: 2757087].
84 Fischer SM, Cervantes L, Fink RM, et al. Apoyo con Cariño: A pilot randomized controlled trial of a patient navigator intervention to improve palliative care outcomes for Latinos with serious illness. J Pain Symptom Manage. 2015;49(4):657-65. Exclusion Code: X6. [pmid: 25240788].
85 Fortney JC, Harman JS, Xu S, et al. The association between rural residence and the use, type, and quality of depression care. J Rural Health. Summer. 2010;26(3):205-13. Exclusion Code: X6. [pmid: 20633088].
86 Fortuna LR, Alegria M, Gao S. Retention in depression treatment among ethnic and racial minority groups in the United States. Depress Anxiety. May. 2010;27(5):485-94. Exclusion Code: X8. [pmid: 20336808].
87 Foulks EF. Commentary: Racial Bias in Diagnosis and Medication of Mentally Ill Minorities in Prisons and Communities. J Am Acad Psychiatry Law. 2004;32(1):34-5. Exclusion Code: X8. [pmid: 15497625].
88 Fox JC, Blank M, Rovnyak VG, et al. Barriers to help seeking for mental disorders in a rural impoverished population. Community Ment Health J. Oct. 2001;37(5):421-36. Exclusion Code: X6. [pmid: 11419519].
89 Francis L, Weiss BD, Senf JH, et al. Does literacy education improve symptoms of depression and self-efficacy in individuals with low literacy and depressive symptoms? A preliminary investigation. J Am Board Fam Med. Jan-Feb. 2007;20(1):23-7. Exclusion Code: X6. [pmid: 17204731].
90 Fuentes D, Aranda MP. Depression interventions among racial and ethnic minority older adults: a systematic review across 20 years. Am J Geriatr Psychiatry. Nov. 2012;20(11):915-31. Exclusion Code: X4. [pmid: 22828202].
91 Gartlehner G, Forneris CA, Brownley KA, et al. Interventions for the Prevention of Posttraumatic Stress Disorder (PTSD) in Adults After Exposure to Psychological Trauma. Comparative Effectiveness Review No. 109. (Prepared by the RTI-UNC EPC under Contract No. 290-2007-10056-I.). AHRQ Publication No. 13-EHC062-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2013. Exclusion Code: X6.
92 Geller JS, Orkaby A, Cleghorn GD. Impact of a group medical visit program on Latino health-related quality of life. Explore (NY). Mar-Apr. 2011;7(2):94-9. Exclusion Code: X6. [pmid: 21397870].
93 Gitlin LN, Harris LF, McCoy M, et al. A community-integrated home based depression intervention for older African Americans: [corrected] description of the Beat the Blues randomized trial and intervention costs. BMC Geriatr. 2012;12:4. Exclusion Code: X6. [pmid: 22325065].
94 Gitlin LN, Harris LF, McCoy MC, et al. A home-based intervention to reduce depressive symptoms and improve quality of life in older African Americans: a randomized trial. Ann Intern Med. Aug. 20. 2013;159(4):243-52. Exclusion Code: X6. [pmid: 24026257].
95 Gitlin LN, Roth DL, Huang J. Mediators of the impact of a home-based intervention (beat the blues) on depressive symptoms among older African Americans. Psychol Aging. Sep. 2014;29(3):601-11. Exclusion Code: X6. [pmid: 25244479].
96 Gleason H, Hobart M, Bradley L, et al. Gender differences of mental health consumers accessing integrated primary and behavioral care. Psychol Health Med. 2014;19(2):146-52. Exclusion Code: X7. [pmid: 23651391].
97 Goldman HH, Morrissey JP, Rosenheck RA, et al. Lessons from the evaluation of the ACCESS program. Access to Community Care and Effective Services. Psychiatr Serv. Aug. 2002;53(8):967-9. Exclusion Code: X9. [pmid: 12161670].
98 Goodrich DE, Bowersox NW, Abraham KM, et al. Leading from the Middle: Replication of a Re-Engagement Program for Veterans with Mental Disorders Lost to Follow-Up Care. Depression Research & Treatment. 2012:1-10. Exclusion Code: X7.
99 Gray N, Mays MZ, Wolf D, et al. Culturally focused wellness intervention for American Indian women of a small southwest community: associations with alcohol use, abstinence self-efficacy, symptoms of depression, and self-esteem. Am J Health Promot. Nov-Dec. 2010;25(2):e1-10. Exclusion Code: X6. [pmid: 21066905].
100 Grote NK, Zuckoff A, Swartz H, et al. Engaging women who are depressed and economically disadvantaged in mental health treatment. Soc Work. Oct. 2007;52(4):295-308. Exclusion Code: X6. [pmid: 18232240].
101 Hahm HC, Cook BL, Ault-Brutus A, et al. Intersection of race-ethnicity and gender in depression care: screening, access, and minimally adequate treatment. Psychiatr Serv. Mar. 1. 2015;66(3):258-64. Exclusion Code: X8. [pmid: 25727113].
102 Hampton MD. Disparities in mental health service utilization among African Americans with severe mental illness. US. ProQuest Information & Learning. 2007. Exclusion Code: X0.
103 Hansen MC, Cabassa LJ. Pathways to depression care: help-seeking experiences of low-income Latinos with diabetes and depression. J Immigr Minor Health. Dec. 2012;14(6):1097-106. Exclusion Code: X6. [pmid: 22367667].
104 Hauenstein EJ. Testing innovative nursing care: home intervention with depressed rural women. Issues Ment Health Nurs. Jan-Feb. 1996;17(1):33-50. Exclusion Code: X6. [pmid: 8682665].
105 Haughey MT, Calderon Y, Torres S, et al. Identification of depression in an inner-city population using a simple screen. Acad Emerg Med. Dec. 2005;12(12):1221-6. Exclusion Code: X6. [pmid: 16293899].
106 Hay JW, Katon WJ, Ell K, et al. Cost-effectiveness analysis of collaborative care management of major depression among low-income, predominantly Hispanics with diabetes. Value Health. Mar-Apr. 2012;15(2):249-54. Exclusion Code: X6. [pmid: 22433755].
107 Heilemann MV, Pieters HC, Kehoe P, et al. Schema therapy, motivational interviewing, and collaborative-mapping as treatment for depression among low income, second generation Latinas. J Behav Ther Exp Psychiatry. Dec. 2011;42(4):473-80. Exclusion Code: X6. [pmid: 21619859].
108 Herman D, Conover S, Felix A, et al. Critical Time Intervention: an empirically supported model for preventing homelessness in high risk groups. J Prim Prev. Jul. 2007;28(3-4):295-312. Exclusion Code: X9. [pmid: 17541827].
109 Hinton L, Apesoa-Varano EC, Gonzalez HM, et al. Falling through the cracks: gaps in depression treatment among older Mexican-origin and white men. Int J Geriatr Psychiatry. Dec. 2012;27(12):1283-90. Exclusion Code: X8. [pmid: 22383214].
110 Horvitz-Lennon M, Donohue JM, Lave JR, et al. The effect of race-ethnicity on the comparative effectiveness of clozapine among Medicaid beneficiaries. Psychiatr Serv. Mar. 1. 2013;64(3):230-7. Exclusion Code: X8. [pmid: 23242347].
111 Horvitz-Lennon M, McGuire TG, Alegria M, et al. Racial and ethnic disparities in the treatment of a Medicaid population with schizophrenia. Health Serv Res. Dec. 2009;44(6):2106-22. Exclusion Code: X8. [pmid: 19780855].
112 Horvitz-Lennon M, Zhou D, Normand SL, et al. Racial and ethnic service use disparities among homeless adults with severe mental illnesses receiving ACT. Psychiatr Serv. Jun. 2011;62(6):598-604. Exclusion Code: X8. [pmid: 21632726].
113 Houlihan BV, Jette A, Friedman RH, et al. A pilot study of a telehealth intervention for persons with spinal cord dysfunction. Spinal Cord. Sep. 2013;51(9):715-20. Exclusion Code: X6. [pmid: 23752260].
114 Howell EA, Balbierz A, Wang J, et al. Reducing postpartum depressive symptoms among black and Latina mothers: a randomized controlled trial. Obstet Gynecol. May. 2012;119(5):942-9. Exclusion Code: X6. [pmid: 22488220].
115 Hudley C, Durvasula R, Jones D, et al. Examining the Complexities Between Health Disparities and Poverty. American Psychological Association. Washington, DC. March. 2014. https://www.apa.org/pi/ses/resources/poverty-complexities-bibliography.pdf. Exclusion Code: X4.
116 Husaini BA, Castor RS, Whitten-Stovall R, et al. An evaluation of a therapeutic health program for the black elderly. J Health Soc Policy. 1990;2(2):67-85. Exclusion Code: X6. [pmid: 10111763].
117 Interian A, Ang A, Gara MA, et al. Stigma and depression treatment utilization among Latinos: utility of four stigma measures. Psychiatr Serv. Apr. 2010;61(4):373-9. Exclusion Code: X8. [pmid: 20360276].
118 Interian A, Ang A, Gara MA, et al. The long-term trajectory of depression among Latinos in primary care and its relationship to depression care disparities. Gen Hosp Psychiatry. Mar-Apr. 2011;33(2):94-101. Exclusion Code: X8. [pmid: 21596201].
119 Interian A, Lewis-Fernandez R, Dixon LB. Improving treatment engagement of underserved U.S. racial-ethnic groups: a review of recent interventions. Psychiatr Serv. Mar. 1. 2013;64(3):212-22. Exclusion Code: X6. [pmid: 23203442].
120 Interian A, Martinez I, Rios LI, et al. Adaptation of a motivational interviewing intervention to improve antidepressant adherence among Latinos. Cultur Divers Ethnic Minor Psychol. Apr. 2010;16(2):215-25. Exclusion Code: X6. [pmid: 20438160].
121 Ishikawa RZ, Cardemil EV, Alegria M, et al. Uptake of depression treatment recommendations among Latino primary care patients. Psychol Serv. Nov. 2014;11(4):421-32. Exclusion Code: X6. [pmid: 24512538].
122 Jaycox LH, Miranda J, Meredith LS, et al. Impact of a primary care quality improvement intervention on use of psychotherapy for depression. Ment Health Serv Res. Jun. 2003;5(2):109-20. Exclusion Code: X6. [pmid: 12801074].
123 Johnsen M, Samberg L, Calsyn R, et al. Case management models for persons who are homeless and mentally ill: the ACCESS demonstration project. Access to Community Care and Effective Services and Supports. Community Ment Health J. Aug. 1999;35(4):325-46. Exclusion Code: X9. [pmid: 10452700].
124 Jones ED, Beck-Little R. The use of reminiscence therapy for the treatment of depression in rural-dwelling older adults. Issues Ment Health Nurs. Apr-May. 2002;23(3):279-90. Exclusion Code: X6. [pmid: 11942192].
125 Kafali N, Cook B, Canino G, et al. Cost-effectiveness of a randomized trial to treat depression among Latinos. J Ment Health Policy Econ. Jun. 2014;17(2):41-50. Exclusion Code: X6. [pmid: 25153092].
126 Kales HC, Mellow AM, Neugroschi JA. Race and depression. Geriatrics. 2006;61(5):18-21. Exclusion Code: X8. [pmid: 16649814].
127 Kashner TM, Trivedi MH, Wicker A, et al. The impact of nonclinical factors on care use for patients with depression: A StarD report. CNS Neurosci Ther. Win. 2009. 2009;15(4):320-32. Exclusion Code: X7. [pmid: 19712127].
128 Kaslow NJ, Leiner AS, Reviere S, et al. Suicidal, abused African American women's response to a culturally informed intervention. J Consult Clin Psychol. Aug. 2010;78(4):449-58. Exclusion Code: X6. [pmid: 20658802].
129 Katon W, Russo J, Reed SD, et al. A randomized trial of collaborative depression care in obstetrics and gynecology clinics: socioeconomic disadvantage and treatment response. Am J Psychiatry. Jan. 2015;172(1):32-40. Exclusion Code: X8. [pmid: 25157500].
130 Keenan TE, Yu A, Cooper LA, et al. Racial patterns of cardiovascular disease risk factors in serious mental illness and the overall U.S. Population. Schizophr Res. 2013;150(1):211-6. Exclusion Code: X4. [pmid: 23916188].
131 Kelly ELP, Fenwick KML, Barr NMSW, et al. A Systematic Review of Self-Management Health Care Models for Individuals With Serious Mental Illnesses. Psychiatr Serv. 2014. Nov. 01. 2014;65(11):1300. Exclusion Code: X7. [pmid: 25023057].
132 Kelly VG, Merrill GS, Shumway M, et al. Outreach, engagement, and practical assistance: essential aspects of PTSD care for urban victims of violent crime. Trauma Violence Abuse. Jul. 2010;11(3):144-56. Exclusion Code: X6. [pmid: 20554505].
133 Kelly-Navarro S. A program evaluation of a community-based family support program: From the participants' perspective. US. ProQuest Information & Learning. 1999. Exclusion Code: X0.
134 Kenny DA, Calsyn RJ, Morse GA, et al. Evaluation of treatment programs for persons with severe mental illness: moderator and mediator effects. Eval Rev. Aug. 2004;28(4):294-324. Exclusion Code: X6. [pmid: 15245622].
135 Kilbourne AM, Abraham KM, Goodrich DE, et al. Cluster randomized adaptive implementation trial comparing a standard versus enhanced implementation intervention to improve uptake of an effective re-engagement program for patients with serious mental illness. Implementation science. 2013:136. Exclusion Code: X7. [pmid: 24252648].
136 Kogan JN, Bauer MS, Dennehy EB, et al. Increasing minority research participation through collaboration with community outpatient clinics: the STEP-BD Community Partners Experience. Clin Trials. Aug. 2009;6(4):344-54. Exclusion Code: X4. [pmid: 19587069].
137 Kristofco RE, Lorenzi NM. How quality improvement interventions can address disparities in depression. J Contin Educ Health Prof. Fall. Suppl 1. 2007;27:S33-9. Exclusion Code: X9. [pmid: 18085577].
138 Kupfer DJ, Axelson DA, Birmaher B, et al. Bipolar disorder center for Pennsylvanians: implementing an effectiveness trial to improve treatment for at-risk patients. Psychiatr Serv. Jul. 2009;60(7):888-97. Exclusion Code: X6. [pmid: 19564218].
139 Le HN, Perry DF, Stuart EA. Randomized controlled trial of a preventive intervention for perinatal depression in high-risk Latinas. J Consult Clin Psychol. Apr. 2011;79(2):135-41. Exclusion Code: X6. [pmid: 21319897].
140 Le HN, Zmuda J, Perry DF, et al. Transforming an evidence-based intervention to prevent perinatal depression for low-income Latina immigrants. Am J Orthopsychiatry. Jan. 2010;80(1):34-45. Exclusion Code: X6. [pmid: 20397987].
141 Lewis-Fernandez R, Aggarwal NK, Baarnhielm S, et al. Culture and psychiatric evaluation: operationalizing cultural formulation for DSM-5. Psychiatry. Summer. 2014;77(2):130-54. Exclusion Code: X6. [pmid: 24865197].
142 Lichtenberg PA. The DOUR Project: A program of depression research in geriatric rehabilitation minority inpatients. Rehabil Psychol. 1997;42(2):103-14. Exclusion Code: X6.
143 Littman AJ, Damschroder LJ, Verchinina L, et al. National evaluation of obesity screening and treatment among veterans with and without mental health disorders. Gen Hosp Psychiatry. 2015;37(1):7-13. Exclusion Code: X7. [pmid: 25500194].
144 Markowitz JC, Patel SR, Balan IC, et al. Toward an adaptation of interpersonal psychotherapy for Hispanic patients with DSM-IV major depressive disorder. J Clin Psychiatry. Feb. 2009;70(2):214-22. Exclusion Code: X9. [pmid: 19192460].
145 McGuire TG, Alegria M, Cook BL, et al. Implementing the Institute of Medicine definition of disparities: an application to mental health care. Health Serv Res. Oct. 2006;41(5):1979-2005. Exclusion Code: X8. [pmid: 16987312].
146 Min SY, Wong YL, Rothbard AB. Outcomes of shelter use among homeless persons with serious mental illness. Psychiatr Serv. Mar. 2004;55(3):284-9. Exclusion Code: X9. [pmid: 15001729].
147 Miranda J, Duan N, Sherbourne C, et al. Improving care for minorities: can quality improvement interventions improve care and outcomes for depressed minorities? Results of a randomized, controlled trial. Health Serv Res. Apr. 2003;38(2):613-30. Exclusion Code: X6. [pmid: 12785564].
148 Miranda J, Ong MK, Jones L, et al. Community-partnered evaluation of depression services for clients of community-based agencies in under-resourced communities in Los Angeles. J Gen Intern Med. Oct. 2013;28(10):1279-87. Exclusion Code: X6. [pmid: 23670566].
149 Miranda J, Schoenbaum M, Sherbourne C, et al. Effects of primary care depression treatment on minority patients' clinical status and employment. Arch Gen Psychiatry. Aug. 2004;61(8):827-34. Exclusion Code: X6. [pmid: 15289281].
150 Mizock L, Kaschak E. Women with Serious Mental Illness in Therapy: Intersectional Perspectives. Women Ther. 2015. Jan-Jun. 2015;38(1/2):6-13. Language: English. Entry Date: 20150227. Revision Date: 20150403. Publication Type: journal article. Exclusion Code: X7.
151 Mohamed S. Adaptation of intensive mental health intensive case management to rural communities in the Veterans Health Administration. Psychiatr Q. Mar. 2013;84(1):103-14. Exclusion Code: X9. [pmid: 22729625].
152 Moore DE Jr., Overstreet KM, Like RC, et al. Improving depression care for ethnic and racial minorities: a concept for an intervention that integrates CME planning with improvement strategies. J Contin Educ Health Prof. Fall. Suppl 1. 2007;27:S65-74. Exclusion Code: X6. [pmid: 18085584].
153 Morland LA, Greene CJ, Rosen CS, et al. Telemedicine for anger management therapy in a rural population of combat veterans with posttraumatic stress disorder: a randomized noninferiority trial. J Clin Psychiatry. Jul. 2010;71(7):855-63. Exclusion Code: X6. [pmid: 20122374].
154 Morrison J. Correlations between definitions of the homeless mentally ill population. Hosp Community Psychiatry. Sep. 1989;40(9):952-4. Exclusion Code: X8. [pmid: 2793100].
155 Morrissey J, Calloway M, Johnsen M, et al. Service system performance and integration: a baseline profile of the ACCESS demonstration sites. Access to Community Care and Effective Services and Supports. Psychiatr Serv. Mar. 1997;48(3):374-80. Exclusion Code: X9. [pmid: 9057241].
156 Morrissey JP, Calloway MO, Thakur N, et al. Integration of service systems for homeless persons with serious mental illness through the ACCESS program. Access to Community Care and Effective Services and Supports. Psychiatr Serv. Aug. 2002;53(8):949-57. Exclusion Code: X9. [pmid: 12161668].
157 Mueser KT, Bond GR, Essock SM, et al. The effects of supported employment in Latino consumers with severe mental illness. Psychiatr Rehabil J. Jun. 2014;37(2):113-22. Exclusion Code: X8. [pmid: 24912060].
158 Mueser KT, Torrey WC, Lynde D, et al. Implementing evidence-based practices for people with severe mental illness. Behav Modif. Jul. 2003;27(3):387-411. Exclusion Code: X7. [pmid: 12841590].
159 Munoz RF, Mendelson T. Toward evidence-based interventions for diverse populations: The San Francisco General Hospital prevention and treatment manuals. J Consult Clin Psychol. Oct. 2005;73(5):790-9. Exclusion Code: X9. [pmid: 16287379].
160 Munoz RF, Ying YW, Bernal G, et al. Prevention of depression with primary care patients: a randomized controlled trial. Am J Community Psychol. Apr. 1995;23(2):199-222. Exclusion Code: X6. [pmid: 7572830].
161 Murdoch M, van Ryn M, Hodges J, et al. Mitigating effect of Department of Veterans Affairs disability benefits for post-traumatic stress disorder on low income. Mil Med. Feb. 2005;170(2):137-40. Exclusion Code: X8. [pmid: 15782835].
162 Naik AD, White CD, Robertson SM, et al. Behavioral health coaching for rural-living older adults with diabetes and depression: an open pilot of the HOPE Study. BMC Geriatr. 2012;12:37. Exclusion Code: X6. [pmid: 22828177].
163 Nicolaidis C, McKeever C, Meucci S. A community-based wellness program to reduce depression in African Americans: results from a pilot intervention. Prog Community Health Partnersh. Summer. 2013;7(2):145-52. Exclusion Code: X6. [pmid: 23793245].
164 Nicolaidis C, Wahab S, Trimble J, et al. The Interconnections Project: development and evaluation of a community-based depression program for African American violence survivors. J Gen Intern Med. Apr. 2013;28(4):530-8. Exclusion Code: X6. [pmid: 23150070].
165 O'Malley AS, Forrest CB, Miranda J. Primary care attributes and care for depression among low-income African American women. Am J Public Health. Aug. 2003;93(8):1328-34. Exclusion Code: X6. [pmid: 12893623].
166 Orozco R, Borges G, Medina-Mora ME, et al. A cross-national study on prevalence of mental disorders, service use, and adequacy of treatment among Mexican and Mexican American populations. Am J Public Health. Sep. 2013;103(9):1610-8. Exclusion Code: X8. [pmid: 23865664].
167 O'Toole TP, Pirraglia PA, Dosa D, et al. Building care systems to improve access for high-risk and vulnerable veteran populations. J Gen Intern Med. Nov. Suppl 2. 2011;26:683-8. Exclusion Code: X7. [pmid: 21989622].
168 Padgett DK, Hawkins RL, Abrams C, et al. In their own words: trauma and substance abuse in the lives of formerly homeless women with serious mental illness. Am J Orthopsychiatry. Oct. 2006;76(4):461-7. Exclusion Code: X4. [pmid: 17209714].
169 Pickens J. Serious mental illness: a theoretical framework for health promotion…. 35th Annual Communicating Nursing Research Conference/16th Annual WIN Assembly, “Health Disparities: Meeting the Challenge”. April 18-20, 2002. Palm Springs, California. Commun Nurs Res. 2002;35:167. [pmid: 2002155807]. Language: English. Entry Date: 20021115. Revision Date: 20041105. Publication Type: journal article. Exclusion Code: X4.
170 Pizzi LT, Jutkowitz E, Frick KD, et al. Cost-effectiveness of a community-integrated home-based depression intervention in older African Americans. J Am Geriatr Soc. Dec. 2014;62(12):2288-95. Exclusion Code: X6. [pmid: 25516025].
171 Podorefsky DL, McDonald-Dowdell M, Beardslee WR. Adaptation of preventive interventions for a low-income, culturally diverse community. J Am Acad Child Adolesc Psychiatry. Aug. 2001;40(8):879-86. Exclusion Code: X4. [pmid: 11501686].
172 Prabucki K, Wootton E, McCormick R, et al. Evaluating the effectiveness of a residential rehabilitation program for homeless veterans. Psychiatr Serv. Apr. 1995;46(4):372-5. Exclusion Code: X6. [pmid: 7788459].
173 Pratt SI, Bartels SJ, Mueser KT, et al. Feasibility and effectiveness of an automated telehealth intervention to improve illness self-management in people with serious psychiatric and medical disorders. Psychiatr Rehabil J. Dec. 2013;36(4):297-305. Exclusion Code: X7. [pmid: 24320837].
174 Ramos Z, Alegria M. Cultural adaptation and health literacy refinement of a brief depression intervention for Latinos in a low-resource setting. Cultur Divers Ethnic Minor Psychol. Apr. 2014;20(2):293-301. Exclusion Code: X9. [pmid: 24588455].
175 Randolph F, Blasinsky M, Leginski W, et al. Creating integrated service systems for homeless persons with mental illness: the ACCESS Program. Access to Community Care and Effective Services and Supports. Psychiatr Serv. Mar. 1997;48(3):369-73. Exclusion Code: X9. [pmid: 9057240].
176 Randolph F, Blasinsky M, Morrissey JP, et al. Overview of the ACCESS Program. Access to Community Care and Effective Services and Supports. Psychiatr Serv. Aug. 2002;53(8):945-8. Exclusion Code: X9. [pmid: 12161667].
177 Reilly S, Planner C, Gask L, et al. Collaborative care approaches for people with severe mental illness. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2013. Exclusion Code: X6.
178 Reyes-Gibby CC, Anderson KO, Shete S, et al. Early referral to supportive care specialists for symptom burden in lung cancer patients: a comparison of non-Hispanic whites, Hispanics, and non-Hispanic blacks. Cancer. Feb. 1. 2012;118(3):856-63. Exclusion Code: X6. [pmid: 21751190].
179 Rosenbaum S. Rehabilitation to prevent premature mortality among people with serious mental illness. International Journal of Therapy & Rehabilitation. 2013;20(11):528-9. Language: English. Entry Date: 20131220. Revision Date: 20131220. Publication Type: journal article. Exclusion Code: X3.
180 Rosenheck R, Fontana A, Cottrol C. Effect of clinician-veteran racial pairing in the treatment of posttraumatic stress disorder. Am J Psychiatry. Apr. 1995;152(4):555-63. Exclusion Code: X8. [pmid: 7694904].
181 Rosenheck R, Morrissey J, Lam J, et al. Service delivery and community: social capital, service systems integration, and outcomes among homeless persons with severe mental illness. Health Serv Res. Aug. 2001;36(4):691-710. Exclusion Code: X9. [pmid: 11508635].
182 Rosenheck RA, Resnick SG, Morrissey JP. Closing service system gaps for homeless clients with a dual diagnosis: integrated teams and interagency cooperation. J Ment Health Policy Econ. Jun. 2003;6(2):77-87. Exclusion Code: X6. [pmid: 14578540].
183 Saw A, Kim J, Lim J, et al. Smoking cessation counseling for Asian immigrants with serious mental illness: using RE-AIM to understand challenges and lessons learned in primary care-behavioral health integration. Health Promot Pract. Sep. 2013;14(5 Suppl):70S-9S. Exclusion Code: X8. [pmid: 23667056].
184 Schraufnagel TJ, Wagner AW, Miranda J, et al. Treating minority patients with depression and anxiety: what does the evidence tell us?. Gen Hosp Psychiatry. Jan-Feb. 2006;28(1):27-36. Exclusion Code: X6. [pmid: 16377362].
185 Seng JS, Kohn-Wood LP, Odera LA. Exploring racial disparity in posttraumatic stress disorder diagnosis: implications for care of African American women. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2005;34(4):521-30. Exclusion Code: X8. [pmid: 16020422].
186 Shellman J, Mokel M. Overcoming barriers to conducting an intervention study of depression in an older African American population. J Transcult Nurs. Oct. 2010;21(4):361-9. Exclusion Code: X6. [pmid: 20592056].
187 Simoni JM, Wiebe JS, Sauceda JA, et al. A preliminary RCT of CBT-AD for adherence and depression among HIV-positive Latinos on the U.S.-Mexico border: the Nuevo Dia study. AIDS Behav. Oct. 2013;17(8):2816-29. Exclusion Code: X6. [pmid: 23812892].
188 Smith T. Providers use foundation grant to improve mental health care for rural women. Health Care Strateg Manage. Oct. 1996;14(10):14-6. Exclusion Code: X9. [pmid: 10161707].
189 Sparks E The challenges facing community health centers in the 1990s: A voice from the inner city Lykes MB Banuazizi A Liem R Morris M Myths about the powerless: Contesting social inequalities Philadelphia, PA, US Temple University Press 1996237-57Exclusion Code: X6
190 Spoont MR, Nelson DB, Murdoch M, et al. Are there racial/ethnic disparities in va ptsd treatment retention?. Depress Anxiety. Jun. 2015;32(6):415-25. Exclusion Code: X8. [pmid: 25421265].
191 Sridhara S. Continuity of care for schizophrenia treatment in Maryland Medicaid. US. ProQuest Information & Learning. 2011. Exclusion Code: X0.
192 Stacciarini JM. Focus groups: examining a community-based group intervention for depressed Puerto Rican women. Issues Ment Health Nurs. Jul. 2008;29(7):679-700. Exclusion Code: X8. [pmid: 18592421].
193 Steadman HJ, Cocozza JJ, Dennis DL, et al. Successful program maintenance when federal demonstration dollars stop: the ACCESS program for homeless mentally ill persons. Adm Policy Ment Health. Jul. 2002;29(6):481-93. Exclusion Code: X9. [pmid: 12469702].
194 Steinberg DM, Askew S, Lanpher MG, et al. The effect of a “maintain, don't gain” approach to weight management on depression among black women: results from a randomized controlled trial. Am J Public Health. Sep. 2014;104(9):1766-73. Exclusion Code: X6. [pmid: 25033150].
195 Sullivan G, Sherbourne C, Chavira DA, et al. Does a quality improvement intervention for anxiety result in differential outcomes for lower-income patients?. Am J Psychiatry. Feb. 2013;170(2):218-25. Exclusion Code: X8. [pmid: 23377641].
196 Surkan PJ, Gottlieb BR, McCormick MC, et al. Impact of a health promotion intervention on maternal depressive symptoms at 15 months postpartum. Matern Child Health J. Jan. 2012;16(1):139-48. Exclusion Code: X6. [pmid: 21153759].
197 Susser E, Valencia E, Berkman A, et al. Human immunodeficiency virus sexual risk reduction in homeless men with mental illness. Arch Gen Psychiatry. Mar. 1998;55(3):266-72. Exclusion Code: X8. [pmid: 9510221].
198 Szanton SL, Thorpe RJ Jr., Gitlin LN. Beat the Blues decreases depression in financially strained older African-American adults. Am J Geriatr Psychiatry. Jul. 2014;22(7):692-7. Exclusion Code: X6. [pmid: 23954036].
199 Tondora J, O'Connell M, Miller R, et al. A clinical trial of peer-based culturally responsive person-centered care for psychosis for African Americans and Latinos. Clin Trials. Aug. 2010;7(4):368-79. Exclusion Code: X9. [pmid: 20571133].
200 Townsend TG, Hawkins SR, Batts AL. Stress and stress reduction among African American women: a brief report. J Prim Prev. Nov. 2007;28(6):569-82. Exclusion Code: X6. [pmid: 18273708].
201 Tran AN, Ornelas IJ, Kim M, et al. Results from a pilot promotora program to reduce depression and stress among immigrant Latinas. Health Promot Pract. May. 2014;15(3):365-72. Exclusion Code: X6. [pmid: 24334543].
202 Tsai J, Desai RA, Rosenheck RA. Racial comparison of therapeutic support, service use, and satisfaction among male outpatients with severe mental illness. Psychiatr Q. 2012;83(4):509-19. Exclusion Code: X7. [pmid: 22477639].
203 Twamley EW, Vella L, Burton CZ, et al. The efficacy of supported employment for middle-aged and older people with schizophrenia. Schizophr Res. Mar. 2012;135(1-3):100-4. Exclusion Code: X7. [pmid: 22197080].
204 Valdez CR, Abegglen J, Hauser CT. Fortalezas familiares program: building sociocultural and family strengths in Latina women with depression and their families. Fam Process. Sep. 2013;52(3):378-93. Exclusion Code: X4. [pmid: 24033237].
205 Valdez CR, Padilla B, Moore SM, et al. Feasibility, acceptability, and preliminary outcomes of the Fortalezas Familiares intervention for Latino families facing maternal depression. Fam Process. Sep. 2013;52(3):394-410. Exclusion Code: X6. [pmid: 24033238].
206 Vega WA, Karno M, Alegria M, et al. Research issues for improving treatment of U.S. Hispanics with persistent mental disorders. Psychiatr Serv. Mar. 2007;58(3):385-94. Exclusion Code: X8. [pmid: 17325113].
207 Viron M, Zioto K, Schweitzer J, et al. Behavioral Health Homes: An opportunity to address healthcare inequities in people with serious mental illness. Asian J Psychiatr. 2014;10:10-6. Exclusion Code: X7. [pmid: 25042945].
208 Viswanathan M, Kahwati LC, Golin CE, et al. Medication Therapy Management Interventions in Outpatient Settings. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290201200008i- HHSA29032002T). Rockville, MD. Agency for Healthcare Research and Quality. In progress. 2014. Exclusion Code: X6.
209 Waitzkin H, Getrich C, Heying S, et al. Promotoras as mental health practitioners in primary care: a multi-method study of an intervention to address contextual sources of depression. J Community Health. Apr. 2011;36(2):316-31. Exclusion Code: X6. [pmid: 20882400].
210 Watkins KE, Shaner A, Sullivan G. The role of gender in engaging the dually diagnosed in treatment. Community Ment Health J. Apr. 1999;35(2):115-26. Exclusion Code: X7. [pmid: 10412621].
211 Wei W, Sambamoorthi U, Olfson M, et al. Use of psychotherapy for depression in older adults. Am J Psychiatry. Apr. 2005;162(4):711-7. Exclusion Code: X8. [pmid: 15800143].
212 Weinert C, Cudney S, Comstock B, et al. Computer intervention impact on psychosocial adaptation of rural women with chronic conditions. Nurs Res. Mar-Apr. 2011;60(2):82-91. Exclusion Code: X6. [pmid: 21358372].
213 Weinstein LC, Lanoue MD, Plumb JD, et al. A primary care-public health partnership addressing homelessness, serious mental illness, and health disparities. J Am Board Fam Med. May-Jun. 2013;26(3):279-87. Exclusion Code: X9. [pmid: 23657696].
214 Wells KB, Jones L, Chung B, et al. Community-partnered cluster-randomized comparative effectiveness trial of community engagement and planning or resources for services to address depression disparities. J Gen Intern Med. Oct. 2013;28(10):1268-78. Exclusion Code: X6. [pmid: 23649787].
215 Wells KB, Sherbourne CD, Miranda J, et al. The cumulative effects of quality improvement for depression on outcome disparities over 9 years: results from a randomized, controlled group-level trial. Med Care. Nov. 2007;45(11):1052-9. Exclusion Code: X7. [pmid: 18049345].
216 Wetherell JL, Ayers CR, Sorrell JT, et al. Modular psychotherapy for anxiety in older primary care patients. Am J Geriatr Psychiatry. Jun. 2009;17(6):483-92. Exclusion Code: X6. [pmid: 19461257].
217 Whealin JM, Stotzer RL, Pietrzak RH, et al. Deployment-related sequelae and treatment utilization in rural and urban war veterans in Hawaii. Psychol Serv. Feb. 2014;11(1):114-23. Exclusion Code: X6. [pmid: 24099457].
218 Whitley R, Lawson WB. The psychiatric rehabilitation of African Americans with severe mental illness. Psychiatr Serv. 2010;61(5):508-11. Exclusion Code: X8. [pmid: 20439373].
219 Wicks MN, Bolden L, Mynatt S, et al. INSIGHT potentially prevents and treats depressive and anxiety symptoms in black women caring for chronic hemodialysis recipients. Nephrol Nurs J. Nov-Dec. 2007;34(6):623-9. Exclusion Code: X6. [pmid: 18203570].
220 Wilbur J, Zenk S, Wang E, et al. Neighborhood characteristics, adherence to walking, and depressive symptoms in midlife African American women. J Womens Health (Larchmt). Aug. 2009;18(8):1201-10. Exclusion Code: X6. [pmid: 19630546].
221 Winters CA, Cudney S, Sullivan T. Expressions of depression in rural women with chronic illness. Rural Remote Health. Oct-Dec. 2010;10(4):1533. Exclusion Code: X6. [pmid: 21126105].
222 Wu S, Ell K, Gross-Schulman SG, et al. Technology-facilitated depression care management among predominantly Latino diabetes patients within a public safety net care system: comparative effectiveness trial design. Contemp Clin Trials. Mar. 2014;37(2):342-54. Exclusion Code: X6. [pmid: 24215775].
223 Yeung A, Hails K, Chang T, et al. A study of the effectiveness of telepsychiatry-based culturally sensitive collaborative treatment of depressed Chinese Americans. BMC Psychiatry. 2011;11:154. Exclusion Code: X10. [pmid: 21943315].
224 Yeung A, Shyu I, Fisher L, et al. Culturally sensitive collaborative treatment for depressed Chinese Americans in primary care. Am J Public Health. Dec. 2010;100(12):2397-402. Exclusion Code: X10. [pmid: 20966373].
225 Yeung A, Yu SC, Fung F, et al. Recognizing and engaging depressed Chinese Americans in treatment in a primary care setting. Int J Geriatr Psychiatry. Sep. 2006;21(9):819-23. Exclusion Code: X6. [pmid: 16955440].
226 Zhang H, Neelarambam K, Schwenke TJ, et al. Mediators of a culturally-sensitive intervention for suicidal African American women. J Clin Psychol Med Settings. Dec. 2013;20(4):401-14. Exclusion Code: X6. [pmid: 23864403].
227 Zivin K, Madden JM, Graves AJ, et al. Cost-related medication nonadherence among beneficiaries with depression following Medicare Part D. The American Journal of Geriatric Psychiatry. 2009;17(12):1068-76. Exclusion Code: X6. [pmid: 20104063].