# Key Informant Interview Methodology

We adhered to the Office of Management and Budget (OMB) requirements and limited standardized question (the list of Guiding Questions [GQs]) to no more than 9 nongovernment-associated individuals. As a result, we did not need to obtain OMB clearance for the interviews.

After review and approval of the completed Disclosure Forms for Conflicts of Interest for the proposed Key Informants (KIs) by the Agency for Healthcare and Quality (AHRQ), we conducted interviews with six selected KIs on three calls; the number of KIs on each call was two, one, and three, respectively. The interviews were a combination of individual KIs based on availability and concordance of perspectives. The Technical Brief's Scientific Director from the Evidence-based Practice Center (EPC), a psychiatrist, led two of the KI interviews; a Co-Investigator from the EPC for this Technical Brief, also a psychiatrist, led one of the interviews. The Task Order Officer (TOO) was in attendance for two of the three discussions, along with other EPC team members who would be authors on the Technical Brief. The KI interviews were one hour each.

Project staff from DESA, Inc., a professional services firm, were also in attendance for the three KI interviews; xxx, Inc. is a small-, minority-, and women-owned business. DESA, Inc. provided professional and extensive notes, similar to transcription, for each interview following the calls. The professional notes, along with summary notes and a summary of findings from all KI interviews, were submitted to the TOO for documentation. Authors identified any unique perspectives from KIs that were not part of the literature review findings.