# Literature Search and Yields

PubMed Original Search, 4/8/2015

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mood Disorders”[Mesh] OR “Schizophrenia and Disorders with Psychotic Features”[Mesh] OR Depression[Mesh] OR ((“Depressive Disorder, Major”[Mesh]) OR “Anxiety Disorders”[Mesh]) OR “Eating Disorders”[Mesh] OR “Personality Disorders”[Mesh] OR ((severe OR serious OR persistent) mental illness[Text Word]))) | 382729 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((((“Cultural Competency”[Mesh]) OR ( “Healthcare Disparities”[Mesh] OR “Health Status Disparities”[Mesh] ))) OR ((((((“Minority Groups”[Mesh]) OR “Sexism”[Mesh]) OR ( “Discrimination (Psychology)”[Mesh] OR “Social Discrimination”[Mesh] OR “Ageism”[Mesh] OR “Racism”[Mesh] )) OR “Rural Population”[Mesh]) OR ( “Socioeconomic Factors”[Mesh] OR “Social Class”[Mesh] )) OR “Sexual Behavior”[Mesh]))) OR ((“Homeless Persons”[Mesh]) OR “African Americans”[Mesh])) OR ((“Homosexuality”[Mesh]) OR “Transgendered Persons”[Mesh]) | 512136 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) | 26654 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intervention Studies”[Mesh] OR “Crisis Intervention”[Mesh] OR intervention)) OR ((“Program Development”[Mesh] OR “Program Evaluation”[Mesh]) OR “Health Services Research”[Mesh]) OR ( “Evidence-Based Medicine”[Mesh] OR “Evidence-Based Practice”[Mesh] OR “Decision Support Techniques”[Mesh] )) | 665190 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #12) | 2769 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #12) Filters: Humans | 2766 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #12) Filters: Humans; English | 2654 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #12) Filters: Publication date from 1980/01/01; Humans; English | 2610 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“United States”[Mesh] OR “United States Government Agencies”[Mesh]) OR “United States Dept. of Health and Human Services”[Mesh]) OR “Research Support, U.S. Gov't, P.H.S.” [Publication Type] | 3228942 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#16 AND #19) Filters: Publication date from 1980/01/01; Humans; English | 1217 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)

Original searches in the following databases were conducted on 4/8/2015; the only limit was publication date from 1/1/1980. Publications were not limited to the United States.

Database | Query | Items Found
Cochrane Reviews | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 7
Cochrane Clinical Trial Registry | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 8
PsycINFO | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 268
CINAHL | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 93
ProQuest Psychology Journals | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 119
Academic Search Premier | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 164
ClinicalTrials.gov | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 9

Original searches in the following databases were conducted on 6/3/2015; the only limit was publication date from 1/1/1980. Publications were not limited to the United States.

Database | Query | Items Found
OpenSIGLE | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 1
NIH RePORTER | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 10
National Quality Measures Clearinghouse | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 10
The Joint Commission | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 0

An original search in the following database was conducted on 6/4/2015; the only limit was publication date from 1/1/1980. Publications were not limited to the United States.

Database | Query | Items Found
National Guidelines Clearinghouse | (severe OR serious OR persistent) mental illness AND (“cultural competency” OR disparities OR disparity OR racism OR sexism OR discrimination OR ageism) | 4

Update searches in the following databases were conducted on 7/1/2015 using the same queries outlined above. The number of new citations (since the original searches) found is provided below.

Database | New Items Found
PubMed | 3
Cochrane Reviews | 0
Cochrane Clinical Trial Registry | 0
PsycINFO | 4
CINAHL | 0
ProQuest Psychology Journals | 11
Academic Search Premier | 3
ClinicalTrials.gov | 1
OpenSIGLE | 0
NIH RePORTER | 1
National Quality Measures Clearinghouse | 0
The Joint Commission | 0
National Guidelines Clearinghouse | 1

A search in PubMed was performed on 8/31/2015 using MeSH headings, “Hispanic Americans,” “Asian Americans,” and “Indians, North Americans” in addition to the search terms outlined above for the original PubMed search:

#39 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((((“Mood Disorders”[Mesh] OR “Schizophrenia and Disorders with Psychotic Features”[Mesh]OR Depression[Mesh] OR ((“Depressive Disorder, Major”[Mesh]) OR “Anxiety Disorders”[Mesh]) OR “Eating Disorders”[Mesh] OR “Personality Disorders”[Mesh] OR ((severe OR serious OR persistent) mental illness[Text Word])))))) AND (((“Intervention Studies”[Mesh] OR “Crisis Intervention”[Mesh] OR intervention)) OR ((“Program Development”[Mesh] OR “Program Evaluation”[Mesh]) OR “Health Services Research”[Mesh]) OR ( “Evidence-Based Medicine”[Mesh] OR “Evidence-Based Practice”[Mesh] OR “Decision Support Techniques”[Mesh] )))) AND (((“United States”[Mesh] OR “United States Government Agencies”[Mesh]) OR “United States Dept. of Health and Human Services”[Mesh]) OR “Research Support, U.S. Government” [Publication Type]) | 7253 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#43 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Hispanic Americans”[Mesh]) OR “Asian Americans”[Mesh]) OR “Indians, North American”[Mesh] | 38150 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#44 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#39 AND #43) | 267 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=44)
#45 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((((“Cultural Competency”[Mesh]) OR ( “Healthcare Disparities”[Mesh] OR “Health Status Disparities”[Mesh] ))) OR ((((((“Minority Groups”[Mesh]) OR “Sexism”[Mesh]) OR ( “Discrimination (Psychology)”[Mesh] OR “Social Discrimination”[Mesh] OR “Ageism”[Mesh] OR “Racism”[Mesh] )) OR “Rural Population”[Mesh]) OR ( “Socioeconomic Factors”[Mesh] OR “Social Class”[Mesh] )) OR “Sexual Behavior”[Mesh]))) OR ((“Homeless Persons”[Mesh]) OR “African Americans”[Mesh])) OR ((“Homosexuality”[Mesh]) OR “Transgendered Persons”[Mesh]) | 523968 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=45)
#46 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#44 NOT #45) | 116 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=46)
#50 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#46 AND #47) Filters: Humans; English | 116 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=50)