# Original Guiding Questions from Study Protocol

1. From available evidence and input from Key Informants (KIs): Describe interventions (types or modalities) to reduce disparities among SMI subgroups. Interventions may address one or more of the following concerns within an SMI subgroup: (a) access to accurate diagnostic evaluation; (b) access to health care, including health care coverage; (c) improving quality of health care; and (d) improving adherence to treatment, response to treatment, or other health outcomes.
  a. What are the goals of the interventions?
  b. What are the components of the interventions?
  c. What are the outcomes of the interventions?
  d. What disparity subgroups are the focus of the interventions?
  e. What are other key characteristics of the disparity subgroups who are eligible for each of the interventions (e.g., age; type, stage, or severity of the SMI condition; or other risk-stratification issues)?
  f. What is the level of staffing and qualifications of staff required (including background, training, and/or necessary certification)?
  g. What are the potential advantages of this type of intervention when compared with other types of interventions or with usual care?
  h. What are the potential disadvantages of these types of interventions, including safety issues and harms?
2. From available evidence and input from KIs: Describe the context for each intervention (type or modality) identified in GQ 1 to reduce disparities among SMI subgroups. Intervention may address one or more of the following concerns: (a) access to accurate diagnostic evaluation; (b) access to health care, including health care coverage; (c) improving quality of health care; and (d) improving response to treatment, adherence to treatment, or other health outcomes.
  a. What is the setting for the intervention; in particular, what is the structure, components, and/or characteristics of the organization(s) providing the intervention?
  b. What other responsibilities do the health professionals (including clinicians) participating in the intervention have for the medical and mental health care of patients with SMI, including transitions of patients from inpatient to outpatient care and vice versa?
  c. What other resources (e.g., health information technology) are needed to provide the intervention?
  d. Does successful implementation of this intervention require changes/cooperation/integration by other service providers?
3. From available evidence: Describe the current evidence about the effectiveness (or comparative effectiveness) of interventions that have been implemented to reduce disparities among SMI subgroups. Interventions may address one or more of the following concerns: (a) access to accurate diagnostic evaluation; (b) access to health care, including health care coverage; (c) improving quality of health care; and (d) improving adherence to treatment, response to treatment, or other health outcomes. Data on a specific intervention will optimally include:
  a. Patient inclusion criteria
  b. Type of intervention
  c. Intervention design and size
  d. Comparator intervention(s) used in comparative effectiveness evaluations
  e. Length of followup
  f. Outcomes
  g. Types of health care professionals providing services in the intervention or targeted by the intervention
  h. Concurrent and prior treatment
  i. Setting of the intervention
  j. Costs and resource used in providing the intervention
  k. Payment considerations (such as availability of insurance coverage)
4. From available evidence and input from KIs, identify gaps in knowledge and future research needs:
  a. Are any interventions to address disparities among SMI subgroups planned by researchers, clinicians, patient advocacy groups, or others but not yet implemented?
  b. In current interventions, are the correct outcomes being measured? Are relevant outcomes being measured with appropriate instruments and data?
  c. What gaps exist in the evidence base for best practices or interventions for addressing disparities in SMI?
  d. What are possible areas of future research?
  e. What are potential long-term (10-year +) developments in this field?