# Summary and Conclusions

## Summary of Patient Populations and/or Safety Issues Not Addressed in This Technical Brief

Several areas are notably not included in this report. We did not review safety issues associated with home health care services, although these services are growing rapidly. We also did not review data on hospice and palliative care services, although we note the need for attention here. Issues related to staff-to-resident aggression or altercations or resident-to-resident aggression, especially in individuals with dementia, pose important potential safety concerns but were not in scope for this report. We also excluded transitional care units in hospitals and inpatient hospital rehabilitation facilities, as well as Veterans Administration (VA) community living centers (although some of the cited research may have included VA sites, we did not examine this setting specifically). Finally, as noted, assisted living facilities may be the fastest growing setting for the care of increasingly vulnerable residents but these were not the focus of our report. That said, it was challenging to determine which studies in the systematic review literature were truly conducted in nursing homes or may have taken place in residential care settings, given inadequate descriptions of settings as well as different terminology used, especially internationally.

## Conclusions

Current discourse about safety and adverse events in nursing homes is largely based on the study of patient safety in the hospital. The four areas currently identified by the Agency for Healthcare Research and Quality for measuring nursing home safety (falls, pressure ulcers, infections, medication errors and adverse drug events) are taken directly from hospital-based concerns. As described here, these four areas alone are likely inadequate to capture the breadth of safety concerns in the nursing home as well as additional measures that might be considered safety issues in the development of a research agenda in this space. Nursing homes differ from hospitals in many ways, including individuals’ resident status and the complexity of their care needs. A large and growing body of literature related to nursing home safety exists, as evidenced by the available literature in this brief. As noted, however, the quality of that research is mixed. In a number of areas that have existing systematic reviews, enough new studies are available that new systematic reviews may be warranted. In terms of primary research, we have laid out not only the current state of the literature, but recommendations for future research. Those recommendations, available in Guiding Question 4, should be taken up by the research community and the funders should consider them as priorities for funding research.