# References

1 Shojania KG, Duncan BW, McDonald KM, et al. Making health care safer: a critical analysis of patient safety practices. Evid Rep Technol Assess (Summ). 2001;(43):i-x. 1. 668. [pmid: 11510252].
2 Levinson D. Adverse Events in Skilled Nursing Facilities: National Incidence Among Medicare Beneficiaries. OEI-06-11-00370. February. 2014. http://oig.hhs.gov/oei/reports/oei-06-11-00370.pdf.
3 Vulnerable populations: who are they?. Am J Manag Care. Nov. 2006;12(13 Suppl):S348-52. [pmid: 17112321].
4 Department of Health and Human Services. Vulnerable Populations. Washington DC. Department of Health and Human Services. http://www.hhs.gov/ohrp/policy/populations/index.html.
5 Centers for Disease Control and Prevention. About CDC’s Office of Minority Health & Health Equity. Atlanta. Centers for Disease Control and Prevention. http://www.cdc.gov/minorityhealth/omhhe.html.
6 Rubenstein LZ, Josephson KR, Robbins AS. Falls in the nursing home. Ann Intern Med. Sep. 15. 1994;121(6):442-51. [pmid: 8053619].
7 Centers for Disease Control and Prevention. Falls in Nursing Homes. Atlanta. Centers for Disease Control and Prevention. 2015. http://www.cdc.gov/HomeandRecreationalSafety/Falls/nursing.html.
8 Center for Medicare & Medicaid Services. Nursing Home Data Compendium 2012 Edition. Centers for Medicare & Medicaid Services. Baltimore MD. 2012. https://www.cms.gov/medicare/provider-enrollment-and-certification/certificationandcomplianc/nhs.html.
9 Werner RM, Konetzka RT, Kim MM. Quality improvement under nursing home compare: the association between changes in process and outcome measures. Med Care. Jul. 2013;51(7):582-8. [pmid: 23756645].
10 Castle NG, Engberg J. The health consequences of using physical restraints in nursing homes. Med Care. Nov. 2009;47(11):1164-73. [pmid: 19786918].
11 Castle NG, Ferguson JC. What is nursing home quality and how is it measured?. Gerontologist. Aug. 2010;50(4):426-42. [pmid: 20631035].
12 Chiu Y, Bero L, Hessol NA, et al. A literature review of clinical outcomes associated with antipsychotic medication use in North American nursing home residents. Health Policy. Jun. 2015;119(6):802-13. [pmid: 25791166].
13 Gruneir A, Mor V. Nursing home safety: current issues and barriers to improvement. Annu Rev Public Health. 2008;29:369-82. [pmid: 18173385].
14 Kapp MB. “At least Mom will be safe there”: the role of resident safety in nursing home quality. Qual Saf Health Care. Jun. 2003;12(3):201-4. [pmid: 12792010].
15 Thomas KS, Hyer K, Castle NG, et al. Patient safety culture and the association with safe resident care in nursing homes. Gerontologist. Dec. 2012;52(6):802-11. [pmid: 22383542].
16 An HM, Baek EH, Jang S, et al. Efficacy of Lactic Acid Bacteria (LAB) supplement in management of constipation among nursing home residents. Nutr J. 2010;9:5. [pmid: 20137076].
17 National Quality Forum. Patient Safety 2015: Final Technical Report. Washington, DC. National Quality Forum. February. 2016. http://www.qualityforum.org/Publications/2016/02/Patient_Safety_2015_Final_Report.aspx.
18 Whiting P, Savović J, Higgins J, et al. ROBIS: A new tool to assess risk of bias in systematic reviews was developed. Jnl Clin Epi. 2016;69:1-39.
19 PSO Privacy Protection Center. Common Formats for Event Reporting - Nursing Home Version 0.1 Beta Vienna, Virginia. https://www.psoppc.org/psoppc_web/publicpages/nursinghome.
20 Centers for Medicare & Medicaid Services. Minimum Data Set, Version 3.0 (MDS 3.0). Baltimore MD. Centers for Medicare and Medicaid Services. 2010. https://www.cms.gov/NursingHomeQualityInits/45_NHQIMDS30TrainingMaterials.asp#TopOPage.
21 Centers for Medicare & Medicaid Services. CMS Nursing Home Compare Quality Measures. Baltimore MD. Centers for Medicare and Medicaid Services. https://www.medicare.gov/NursingHomeCompare/About/Quality-Measures-Info.html.
22 Studdert DM, Spittal MJ, Mello MM, et al. Relationship between quality of care and negligence litigation in nursing homes. N Engl J Med. Mar. 31. 2011;364(13):1243-50. [pmid: 21449787].
23 Handler SM, Wright RM, Ruby CM, et al. Epidemiology of medication-related adverse events in nursing homes. Am J Geriatr Pharmacother. Sep. 2006;4(3):264-72. [pmid: 17062328].
24 Kind AJH, Smith MA. Documentation of Mandated Discharge Summary Components in Transitions from Acute to Subacute Care. Henriksen K, Battles JB, Keyes MA, Grady ML, editors. Advances in Patient Safety: New Directions and Alternative Approaches (Vol. 2: Culture and Redesign). Rockville (MD). Agency for Healthcare Research and Quality (US). 2008. Aug.
25 Kind AJ, Thorpe CT, Sattin JA, et al. Provider characteristics, clinical-work processes and their relationship to discharge summary quality for sub-acute care patients. J Gen Intern Med. Jan. 2012;27(1):78-84. [pmid: 21901489].
26 Bartel A, Chan C, Kim S. Should hospitals keep their patients longer? The role of inpatient and outpatient care in reducing readmissions. Cambridge MA. National Bureau of Economic Research. 2014. http://www.nber.org/papers/w20499.
27 Bell S, Vasilevskis E, Saraf A, et al. Geriatric syndromes in patients transferred to skilled nursing facilities. J Am Geriatr Soc. 2016. (In press).
28 Burke RE, Rooks SP, Levy C, et al. Identifying Potentially Preventable Emergency Department Visits by Nursing Home Residents in the United States. J Am Med Dir Assoc. May. 1. 2015;16(5):395-9. [pmid: 25703449].
29 Kramer A, Fish R, Min S. Community Discharge and Rehospitalization Outcome Measures (Fiscal Year 2011). MedPAC. Washington, DC. Providigm, LLC. 2013. http://www.medpac.gov/documents/contractor-reports/apr13_communitydischarge_contractor.pdf.
30 Office of Inspector General. Skilled Nursing Facilities Often Fail to Meet Care Planning and Discharge Planning Requirements. OEI-02-09-00201. 27. Feb. 2013. Available from http://oig.hhs.gov/oei/reports/oei-02-09-00201.asp.
31 King BJ, Gilmore-Bykovskyi AL, Roiland RA, et al. The consequences of poor communication during transitions from hospital to skilled nursing facility: a qualitative study. J Am Geriatr Soc. Jul. 2013;61(7):1095-102. [pmid: 23731003].
32 Donovan JL, Kanaan AO, Gurwitz JH, Tjia J, Cutrona SL, Garber L, Preusse P, Field TS. A Pilot Health Information Technology-Based Effort to Increase the Quality of Transitions From Skilled Nursing Facility to Home: Compelling Evidence of High Rate of Adverse Outcomes. J Am Med Dir Assoc. 2015. Dec. 23. [pii: S1525-8610(15)00708-2].
33 Hempel S, Maggard-Gibbons M, Nguyen DK, et al. Wrong-Site Surgery, Retained Surgical Items, and Surgical Fires : A Systematic Review of Surgical Never Events. JAMA Surg. Aug. 2015;150(8):796-805. [pmid: 26061125].
34 Maaskant JM, Vermeulen H, Apampa B, et al. Interventions for reducing medication errors in children in hospital. Cochrane Database Syst Rev. 2015;3:Cd006208. [pmid: 25756542].
35 Charles K, Cannon M, Hall R, et al. Can utilizing a computerized provider order entry (CPOE) system prevent hospital medical errors and adverse drug events?. Perspect Health Inf Manag. 2014;11:1b. [pmid: 25593568].
36 Acheampong F, Anto BP, Koffuor GA. Medication safety strategies in hospitals--a systematic review. Int J Risk Saf Med. 2014;26(3):117-31. [pmid: 25214157].
37 Clay-Williams R, Nosrati H, Cunningham FC, et al. Do large-scale hospital- and system-wide interventions improve patient outcomes: a systematic review. BMC Health Serv Res. 2014;14:369. [pmid: 25187292].
38 Manias E, Kinney S, Cranswick N, et al. Interventions to reduce medication errors in pediatric intensive care. Ann Pharmacother. Oct. 2014;48(10):1313-31. [pmid: 25059205].
39 Rinke ML, Bundy DG, Velasquez CA, et al. Interventions to reduce pediatric medication errors: a systematic review. Pediatrics. Aug. 2014;134(2):338-60. [pmid: 25022737].
40 Keers RN, Williams SD, Cooke J, et al. Impact of interventions designed to reduce medication administration errors in hospitals: a systematic review. Drug Saf. May. 2014;37(5):317-32. [pmid: 24760475].
41 Berger Z, Flickinger TE, Pfoh E, et al. Promoting engagement by patients and families to reduce adverse events in acute care settings: a systematic review. BMJ Qual Saf. Jul. 2014;23(7):548-55. [pmid: 24336575].
42 Ojeleye O, Avery A, Gupta V, et al. The evidence for the effectiveness of safety alerts in electronic patient medication record systems at the point of pharmacy order entry: a systematic review. BMC Med Inform Decis Mak. 2013;13:69. [pmid: 23816138].
43 Shekelle PG. Nurse-patient ratios as a patient safety strategy: a systematic review. Ann Intern Med. Mar. 5. 2013;158(5 Pt 2):404-9. [pmid: 23460097].
44 Weaver SJ, Lubomksi LH, Wilson RF, et al. Promoting a culture of safety as a patient safety strategy: a systematic review. Ann Intern Med. Mar. 5. 2013;158(5 Pt 2):369-74. [pmid: 23460092].
45 Shekelle PG, Wachter RM, Pronovost PJ, et al. Making health care safer II: an updated critical analysis of the evidence for patient safety practices. Evid Rep Technol Assess (Full Rep). Mar. 2013;(211):1-945. [pmid: 24423049].
46 Shekelle PG, Pronovost PJ, Wachter RM, et al. Advancing the science of patient safety. Ann Intern Med. May. 17. 2011;154(10):693-6. [pmid: 21576538].
47 Sullivan N, Schoelles KM. Preventing in-facility pressure ulcers as a patient safety strategy: a systematic review. Ann Intern Med. Mar. 5. 2013;158(5 Pt 2):410-6. [pmid: 23460098].
48 Reston JT, Schoelles KM. In-facility delirium prevention programs as a patient safety strategy: a systematic review. Ann Intern Med. Mar. 5. 2013;158(5 Pt 2):375-80. [pmid: 23460093].
49 Miake-Lye IM, Hempel S, Ganz DA, et al. Inpatient Fall Prevention Programs as a Patient Safety Strategy A Systematic Review. Annals of Internal Medicine. 2013;158(5_Part_2):390-6. [pmid: 23460095].
50 DiBardino D, Cohen ER, Didwania A. Meta-analysis: Multidisciplinary fall prevention strategies in the acute care inpatient population. Journal of Hospital Medicine. 2012;7(6):497-503. [pmid: 22371369].
51 Oliver D, Connelly JB, Victor CR, et al. Strategies to prevent falls and fractures in hospitals and care homes and effect of cognitive impairment: systematic review and meta-analyses. Bmj. Jan. 13. 2007;334(7584):82. [pmid: 17158580].
52 Gschwind YJ, Kressig RW, Lacroix A, et al. A best practice fall prevention exercise program to improve balance, strength/power, and psychosocial health in older adults: study protocol for a randomized controlled trial. BMC geriatrics. 2013;13(1):105. [pmid: 24106864].
53 Luk JK, Chiu PK, Chu LW. Factors affecting institutionalization in older Hong Kong Chinese patients after recovery from acute medical illnesses. Arch Gerontol Geriatr. Sep–Oct. 2009;49(2):e110-4. [pmid: 19095312].
54 Eginger KH, Yarborough LL, Inge LD, et al. Medication Errors in HIV-Infected Hospitalized Patients: A Pharmacist’s Impact. Annals of Pharmacotherapy 2013. July. 1. 2013;47(7–8):953-60.
55 Klopotowska J, Kuiper R, van Kan H, et al. On-ward participation of a hospital pharmacist in a Dutch intensive care unit reduces prescribing errors and related patient harm: an intervention study. Critical Care 2010. 10. 04. 2010;14(5):1-11.
56 Midlöv P, Holmdahl L, Eriksson T, et al. Medication report reduces number of medication errors when elderly patients are discharged from hospital. Pharmacy World & Science 2008. 01. 01. 2008;30(1):92-8.
57 Shulman R, McKenzie CA, Landa J, et al. Pharmacist’s review and outcomes: Treatment-enhancing contributions tallied, evaluated, and documented (PROTECTED-UK). Journal of Critical Care. 8. 2015;30(4):808-13. [pmid: 25971871].
58 Gurwitz JH, Field TS, Harrold LR, et al. INcidence and preventability of adverse drug events among older persons in the ambulatory setting. JAMA. 2003;289(9):1107-16. [pmid: 12622580].
59 Mueller SK, Sponsler K, Kripalani S, et al. Hospital-based medication reconciliation practices: A systematic review. Archives of Internal Medicine. 2012;172(14):1057-69. [pmid: 22733210].
60 Leape LL, Cullen DJ, Clapp M, et al. PHarmacist participation on physician rounds and adverse drug events in the intensive care unit. JAMA. 1999;282(3):267-70. [pmid: 10422996].
61 Gazarian M, Graudins LV. Long-term Reduction in Adverse Drug Events: An Evidence-Based Improvement Model. Pediatrics 2012. May. 1. 2012;129(5):e1334-e42.
62 Blank FSJ, Tobin J, Macomber S, et al. A “Back to Basics” Approach to Reduce ED Medication Errors. Journal of Emergency Nursing. 3. 2011;37(2):141-7. [pmid: 21397127].
63 Pham CB, Dickman RL. Minimizing adverse drug events in older patients. Am Fam Physician. 2007;76(12):1837-44. [pmid: 18217523].
64 Spinewine A, Claeys C, Foulon V, et al. Approaches for improving continuity of care in medication management: a systematic review. Int J Qual Health Care. Sep. 2013;25(4):403-17. [pmid: 23639854].
65 Szczepura A, Wild D, Nelson S. Medication administration errors for older people in long-term residential care. BMC Geriatr. 2011;11:82. [pmid: 22151472].
66 Scott-Cawiezell J, Madsen RW, Pepper GA, et al. Medication safety teams’ guided implementation of electronic medication administration records in five nursing homes. Jt Comm J Qual Patient Saf. Jan. 2009;35(1):29-35. [pmid: 19213298].
67 Qian S, Yu P, Hailey DM. The impact of electronic medication administration records in a residential aged care home. Int J Med Inform. Nov. 2015;84(11):966-73. [pmid: 26358850].
68 Wild D, Szczepura A, Nelson S. New barcode checks help reduce drug round errors in care homes. Nurs Manag (Harrow). Sep. 2011;18(5):26-30. [pmid: 21977895].
69 Bates D, Boyle D, Vliet MV, et al. Relationship between medication errors and adverse drug events. Journal of General Internal Medicine 1995. 04. 01. 1995;10(4):199-205.
70 Classen DC, Metzger J. Improving medication safety: the measurement conundrum and where to start. Int J Qual Health Care. Dec. 2003;15(Suppl 1):i41-7. [pmid: 14660522].
71 Conroy S, Sweis D, Planner C, et al. Interventions to Reduce Dosing Errors in Children. Drug Safety 2007. 12. 01. 2007;30(12):1111-25.
72 Kaushal R, Shojania KG, Bates DW. Effects of computerized physician order entry and clinical decision support systems on medication safety: A systematic review. Archives of Internal Medicine. 2003;163(12):1409-16. [pmid: 12824090].
73 Hug B, Witkowski D, Sox C, et al. Adverse Drug Event Rates in Six Community Hospitals and the Potential Impact of Computerized Physician Order Entry for Prevention. Journal of General Internal Medicine 2010. 01. 01. 2010;25(1):31-8.
74 Merandi J, Morvay S, Lewe D, et al. Improvement of medication event interventions through use of an electronic database. American Journal of Health-System Pharmacy 2013. October. 1. 2013;70(19):1708-14.
75 Natali BJ, Varkey AC, Garey KW, et al. Impact of a pharmacotherapy alerting system on medication errors. American Journal of Health-System Pharmacy. January. 1. 2013;70(1):48-52. [pmid: 23261900].
76 Patterson Susan M, Cadogan Cathal A, Kerse N, et al. Interventions to improve the appropriate use of polypharmacy for older people. Cochrane Database of Systematic Reviews. 2014;(10).
77 Whitney J, Phillips L, Aslam R, et al. Guidelines for the treatment of pressure ulcers. Wound Repair and Regeneration. 2006;14(6):663-79. [pmid: 17199832].
78 US Government Accountability Office. Nursing Homes : Federal Monitoring Surveys Demonstrate Continued Understatement of Serious Care Problems and CMS Oversight Weakness. GAO-08-517. May. 2008. http://www.gao.gov/new.items/d08517.pdf.
79 Health Quality Ontario. Management of Chronic Pressure Ulcers: An Evidence-Based Analysis. Ontario Health Technology Assessment Series. 07. 01. 2009;9(3):1-203. [pmid: 23074533].
80 Pressure ulcer prevention: an evidence-based analysis. Ont Health Technol Assess Ser. 2009;9(2):1-104. [pmid: 23074524].
81 Smith ME, Totten A, Hickam DH, et al. Pressure ulcer treatment strategies: a systematic comparative effectiveness review. Ann Intern Med. Jul. 2. 2013;159(1):39-50. [pmid: 23817703].
82 Umscheid C, Mitchell M, Doshi J, et al. Estimating the Proportion of Healthcare-Associated Infections That Are Reasonably Preventable and the Related Mortality and Costs. Infection Control and Hospital Epidemiology. 2011;32(2):101-14. [pmid: 21460463].
83 Gould CV, Umscheid CA, Agarwal RK, et al. Guideline for prevention of catheter-associated urinary tract infections 2009. Infection Control. 2010;31(04):319-20.
84 Lo E, Nicolle L, Classen D, et al. Strategies to Prevent Catheter-Associated Urinary Tract Infections in Acute Care Hospitals. Infection Control & Hospital Epidemiology. 2008;29(Supplement S1):S41-S50. [pmid: 18840088].
85 Lo E, Nicolle LE, Coffin SE, et al. Strategies to Prevent Catheter-Associated Urinary Tract Infections in Acute Care Hospitals: 2014 Update. Infection Control & Hospital Epidemiology. 2014;35(05):464-79. [pmid: 24709715].
86 Meddings J, Rogers MAM, Krein SL, et al. Reducing unnecessary urinary catheter use and other strategies to prevent catheter-associated urinary tract infection: an integrative review. BMJ Quality & Safety. 2014. 09. 27.
87 Meddings J, Rogers MAM, Macy M, et al. Systematic Review and Meta-Analysis: Reminder Systems to Reduce Catheter-Associated Urinary Tract Infections and Urinary Catheter Use in Hospitalized Patients. Clinical Infectious Diseases 2010. September. 1. 2010;51(5):550-60.
88 Safdar N, Abad C. Educational interventions for prevention of healthcare-associated infection: A systematic review. Critical Care Medicine. 2008;36(3):933-40. [pmid: 18431283].
89 Yokoe DS, Anderson DJ, Berenholtz SM, et al. A Compendium of Strategies to Prevent Healthcare-Associated Infections in Acute Care Hospitals: 2014 Updates. American Journal of Infection Control. 8. 2014;42(8):820-8. [pmid: 25087135].
90 Rothenberg M, Marbella A, Pines E, et al. Prevention of Healthcare-Associated Infections. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report/Technology Assessment. 2012;(208).
91 Ranji SR, Shetty K, Posley KA, et al. Prevention of Healthcare–Associated Infections. Prepared by Stanford University–UCSF Evidence-based Practice Center under Contract No. 290-02-0017). AHRQ Publication No. 04(07)-0051-6. Rockville, MD. AHRQ. January. 2007. http://www.ncbi.nlm.nih.gov/books/NBK43982/pdf/TOC.pdf.
92 Zhang YZ, Singh S. Antibiotic stewardship programmes in intensive care units: Why, how, and where are they leading us. World J Crit Care Med. Feb. 4. 2015;4(1):13-28. [pmid: 25685719].
93 Davey P, Brown E, Charani E, et al. Interventions to improve antibiotic prescribing practices for hospital inpatients. Cochrane Database Syst Rev. 2013;4:Cd003543. [pmid: 23633313].
94 Stout A, Ritchie K, Macpherson K. Clinical effectiveness of alcohol-based products in increasing hand hygiene compliance and reducing infection rates: a systematic review. J Hosp Infect. Aug. 2007;66(4):308-12. [pmid: 17655977].
95 Larmer PJ, Tillson TM, Scown FM, et al. Evidence-based recommendations for hand hygiene for health care workers in New Zealand. N Z Med J. Apr. 18. 2008;121(1272):69-81. [pmid: 18425156].
96 Pincock T, Bernstein P, Warthman S, et al. Bundling hand hygiene interventions and measurement to decrease health care-associated infections. Am J Infect Control. May. 2012;40(4 Suppl 1):S18-27. [pmid: 22546269].
97 Cherry MG, Brown JM, Bethell GS, et al. Features of educational interventions that lead to compliance with hand hygiene in healthcare professionals within a hospital care setting. A BEME systematic review: BEME Guide No. 22. Med Teach. 2012;34(6):e406-20. [pmid: 22578050].
98 Gould DJ, Moralejo D, Drey N, et al. Interventions to improve hand hygiene compliance in patient care. Cochrane Database of Systematic Reviews. 2010;(9).
99 Dancer SJ. The role of environmental cleaning in the control of hospital-acquired infection. J Hosp Infect. Dec. 2009;73(4):378-85. [pmid: 19726106].
100 Herzig CT, Stone PW, Castle N, et al. Infection Prevention and Control Programs in US Nursing Homes: Results of a National Survey. J Am Med Dir Assoc. Jan. 1. 2016;17(1):85-8. [pmid: 26712489].
101 Cohen CC, Engberg J, Herzig CT, et al. Nursing Homes in States with Infection Control Training or Infection Reporting Have Reduced Infection Control Deficiency Citations. Infect Control Hosp Epidemiol. Dec. 2015;36(12):1475-6. [pmid: 26350287].
102 Padula WV, Makic MB, Wald HL, et al. Hospital-Acquired Pressure Ulcers at Academic Medical Centers in the United States, 2008–2012: Tracking Changes Since the CMS Nonpayment Policy. Jt Comm J Qual Patient Saf. Jun. 2015;41(6):257-63. [pmid: 25990891].
103 Centers for Disease Control and Prevention. Healthcare-associated Infections (HAI) Progress Report. Atlanta, GA. Centers for Disease Control and Prevention. http://www.cdc.gov/hai/progress-report/index.html.
104 Waters TM, Daniels MJ, Bazzoli GJ, et al. Effect of Medicare’s nonpayment for Hospital-Acquired Conditions: lessons for future policy. JAMA Intern Med. Mar. 2015;175(3):347-54. [pmid: 25559166].
105 Peasah SK, McKay NL, Harman JS, et al. Medicare non-payment of hospital-acquired infections: infection rates three years post implementation. Medicare Medicaid Res Rev. 2013;3(3). [pmid: 24753974].
106 Schuller K, Probst J, Hardin J, et al. Initial impact of Medicare’s nonpayment policy on catheter-associated urinary tract infections by hospital characteristics. Health Policy. Apr. 2014;115(2–3):165-71. [pmid: 24361201].
107 Lee GM, Hartmann CW, Graham D, et al. Perceived impact of the Medicare policy to adjust payment for health care-associated infections. Am J Infect Control. May. 2012;40(4):314-9. [pmid: 22541855].
108 Vlaeyen E, Coussement J, Leysens G, et al. Characteristics and effectiveness of fall prevention programs in nursing homes: a systematic review and meta-analysis of randomized controlled trials. J Am Geriatr Soc. Feb. 2015;63(2):211-21. [pmid: 25641225].
109 Silva RB, Eslick GD, Duque G. Exercise for falls and fracture prevention in long term care facilities: a systematic review and meta-analysis. J Am Med Dir Assoc. Sep. 2013;14(9):685-9.e2. [pmid: 23860265].
110 Chua GT, Wong RY. Association Between Vitamin D Dosing Regimen and Fall Prevention in Long-term Care Seniors. Can Geriatr J. Dec. 2011;14(4):93-9. [pmid: 23251320].
111 Cameron ID, Gillespie LD, Robertson MC, et al. Interventions for preventing falls in older people in care facilities and hospitals. Cochrane Database Syst Rev. 2012;12:Cd005465. [pmid: 23235623].
112 Balzer K, Bremer M, Schramm S, et al. Falls prevention for the elderly. GMS Health Technol Assess. 2012;8:Doc01. [pmid: 22536299].
113 Anderson O, Boshier PR, Hanna GB. Interventions designed to prevent healthcare bed-related injuries in patients. Cochrane Database Syst Rev. 2011;(11):Cd008931. [pmid: 22071860].
114 Cusimano MD, Kwok J, Spadafora K. Effectiveness of multifaceted fall-prevention programs for the elderly in residential care. Inj Prev. Apr. 2008;14(2):113-22. [pmid: 18388232].
115 Sawka AM, Boulos P, Beattie K, et al. Hip protectors decrease hip fracture risk in elderly nursing home residents: a Bayesian meta-analysis. Journal of clinical epidemiology 2007. 04. 23. 2007;60(4):336-44.
116 Sawka AM, Boulos P, Beattie K, et al. Do hip protectors decrease the risk of hip fracture in institutional and community-dwelling elderly? A systematic review and meta-analysis of randomized controlled trials. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA 2005. 12. 01. 2005;16(12):1461-74.
117 Sawka AM, Ismaila N, Cranney A, et al. A scoping review of strategies for the prevention of hip fracture in elderly nursing home residents. PloS one 2010. 03. 03. 2010;5(3):e9515.
118 Santesso N, Carrasco-Labra A, Brignardello-Petersen R. Hip protectors for preventing hip fractures in older people. Cochrane Database of Systematic Reviews. 2014;3:CD001255. [pmid: 24687239].
119 Howe Tracey E, Rochester L, Neil F, et al. Exercise for improving balance in older people. Cochrane Database of Systematic Reviews. 2011;(11).
120 Choi M, Hector M. Effectiveness of intervention programs in preventing falls: a systematic review of recent 10 years and meta-analysis. Journal of the American Medical Directors Association. 2012;13(2):188.e13-21. [pmid: 21680249].
121 Gillespie BM, Chaboyer WP, McInnes E, et al. Repositioning for pressure ulcer prevention in adults. Cochrane Database Syst Rev. 2014;4:Cd009958. [pmid: 24700291].
122 Niederhauser A, VanDeusen Lukas C, Parker V, et al. Comprehensive programs for preventing pressure ulcers: a review of the literature. Adv Skin Wound Care. Apr. 2012;25(4):167-88. quiz 89–90. [pmid: 22441049].
123 Cullum N, Petherick E. Pressure ulcers. BMJ Clin Evid. 2008;2008. [pmid: 19450317].
124 Saha S, Smith MEB, Totten A, et al. Pressure Ulcer Treatment Strategies: Comparative Effectiveness. 2013. May. [pmid: 23785727].
125 Chou R, Dana T, Bougatsos C, et al. Pressure Ulcer Risk Assessment and Prevention: Comparative Effectiveness. 2013. May. [pmid: 23762918].
126 Reddy M, Gill SS, Kalkar SR, et al. Treatment of pressure ulcers: a systematic review. JAMA. Dec. 10. 2008;300(22):2647-62. [pmid: 19066385].
127 Hughes C, Tunney M, Bradley Marie C. Infection control strategies for preventing the transmission of meticillin-resistant Staphylococcus aureus (MRSA) in nursing homes for older people. Cochrane Database of Systematic Reviews. 2013;(11).
128 Sjögren P, Nilsson E, Forsell M, et al. A systematic review of the preventive effect of oral hygiene on pneumonia and respiratory tract infection in elderly people in hospitals and nursing homes: effect estimates and methodological quality of randomized controlled trials. Journal of the American Geriatrics Society 2008. 11. 15. 2008;56(11):2124-30.
129 Uchida M, Pogorzelska-Maziarz M, Smith PW, et al. Infection prevention in long-term care: a systematic review of randomized and nonrandomized trials. Journal of the American Geriatrics Society. 2013;61(4):602-14. [pmid: 23581914].
130 Tjia J, Velten SJ, Parsons C, et al. Studies to reduce unnecessary medication use in frail older adults: a systematic review. Drugs Aging. May. 2013;30(5):285-307. [pmid: 23475597].
131 Alldred DP, Raynor DK, Hughes C, et al. Interventions to optimise prescribing for older people in care homes. Cochrane Database Syst Rev. 2013;2:CD009095. [pmid: 23450597].
132 Forsetlund L, Eike MC, Gjerberg E, et al. Effect of interventions to reduce potentially inappropriate use of drugs in nursing homes: a systematic review of randomised controlled trials. BMC Geriatr. 2011;11:16. [pmid: 21496345].
133 Loganathan M, Singh S, Franklin BD, et al. Interventions to optimise prescribing in care homes: systematic review. Age Ageing. Mar. 2011;40(2):150-62. [pmid: 21262782].
134 Marasinghe KM. Computerised clinical decision support systems to improve medication safety in long-term care homes: a systematic review. BMJ Open. 2015;5(5):e006539. [pmid: 25967986].
135 Fleming A, Browne J, Byrne S. The effect of interventions to reduce potentially inappropriate antibiotic prescribing in long-term care facilities: a systematic review of randomised controlled trials. Drugs Aging. Jun. 2013;30(6):401-8. [pmid: 23444263].
136 LaMantia MA, Scheunemann LP, Viera AJ, et al. Interventions to improve transitional care between nursing homes and hospitals: a systematic review. J Am Geriatr Soc. Apr. 2010;58(4):777-82. [pmid: 20398162].
137 Wallerstedt SM, Kindblom JM, Nylén K, et al. Medication reviews for nursing home residents to reduce mortality and hospitalization: systematic review and meta-analysis. Br J Clin Pharmacol 2014. 02. 18. 2014;78(3):488-97.
138 Clegg A, Siddiqi N, Heaven A, et al. Interventions for preventing delirium in older people in institutional long-term care. Cochrane Database Syst Rev. 2014;1:CD009537. [pmid: 24488526].
139 Simmons SF, Schnelle JF. Individualized feeding assistance care for nursing home residents: staffing requirements to implement two interventions. J Gerontol A Biol Sci Med Sci. Sep. 2004;59(9):M966-73. [pmid: 15472163].
140 Simmons SF, Osterweil D, Schnelle JF. Improving food intake in nursing home residents with feeding assistance: a staffing analysis. J Gerontol A Biol Sci Med Sci. Dec. 2001;56(12):M790-4. [pmid: 11723156].
141 Schnelle JF, Alessi CA, Simmons SF, et al. Translating clinical research into practice: a randomized controlled trial of exercise and incontinence care with nursing home residents. J Am Geriatr Soc. Sep. 2002;50(9):1476-83. [pmid: 12383143].
142 Simmons SF, Keeler E, Zhuo X, et al. Prevention of unintentional weight loss in nursing home residents: a controlled trial of feeding assistance. J Am Geriatr Soc. Aug. 2008;56(8):1466-73. [pmid: 18637983].
143 Bunn D, Jimoh F, Wilsher SH, et al. Increasing fluid intake and reducing dehydration risk in older people living in long-term care: a systematic review. J Am Med Dir Assoc. Feb. 2015;16(2):101-13. [pmid: 25499399].
144 Sollins HL. Office of inspector general report finds skilled nursing facilities “often” fail to meet care planning and discharge planning requirements. Geriatr Nurs. May–Jun. 2013;34(3):233-4. [pmid: 23639913].
145 Reddy M, Gill SS, Rochon PA. Preventing pressure ulcers: a systematic review. JAMA. Aug. 23. 2006;296(8):974-84. [pmid: 16926357].
146 Kane R, et al. Non-pharmacologic Interventions for Agitation and Aggression in Dementia. (in press). 2016.
147 Simmons SF, Babineau S, Garcia E, et al. Quality assessment in nursing homes by systematic direct observation: feeding assistance. J Gerontol A Biol Sci Med Sci. Oct. 2002;57(10):M665-71. [pmid: 12242322].
148 Schnelle JF, Bates-Jensen BM, Chu L, et al. Accuracy of nursing home medical record information about care-process delivery: implications for staff management and improvement. J Am Geriatr Soc. Aug. 2004;52(8):1378-83. [pmid: 15271130].
149 Thomas K. Medicare star ratings allow nursing homes to game the system. New York Times. August. 24. 2014.
150 Munley E. CMS will expand MDS 3.0 Focused Surveys in 2015. Leading Age. 2014. http://www.leadingage.org/CMS_Will_Expand_MDS_3_0_Focused_Surveys_in_2015.aspx.
151 Centers for Medicare & Medicaid Services. CMS Announces Two Medicare Quality Improvement Initiatives. Centers for Medicare & Medicaid Services. Baltimore MD. October. 6. 2014. https://www.cms.gov/Newsroom/MediaReleaseDatabase/Press-releases/2014-Press-releases-items/2014-10-06.html.
152 Bostick JE, Rantz MJ, Flesner MK, et al. Systematic review of studies of staffing and quality in nursing homes. J Am Med Dir Assoc. Jul. 2006;7(6):366-76. [pmid: 16843237].
153 Castle NG. Nursing Home Caregiver Staffing Levels and Quality of Care: A Literature Review. Journal of Applied Gerontology 2008. August. 1. 2008;27(4):375-405.
154 Spilsbury K, Hewitt C, Stirk L, et al. The relationship between nurse staffing and quality of care in nursing homes: a systematic review. Int J Nurs Stud. Jun. 2011;48(6):732-50. [pmid: 21397229].
155 Backhaus R, Verbeek H, van Rossum E, et al. Nurse staffing impact on quality of care in nursing homes: a systematic review of longitudinal studies. J Am Med Dir Assoc. Jun. 2014;15(6):383-93. [pmid: 24529872].
156 Dellefield ME, Castle NG, McGilton KS, et al. The Relationship Between Registered Nurses and Nursing Home Quality: An Integrative Review (2008–2014). Nurs Econ. Mar–Apr. 2015;33(2):95-108. 16. [pmid: 26281280].
157 Breunig IWA, Ribar D. Developing a Community Discharge Measure for Medicare Nursing Home Residents. Academy Health. 2015.
158 Centers for Medicare & Medicaid Services. Nursing Home Compare Five-Star Quality Rating System: Year Five Report. 2014. https://www.cms.gov/Medicare/Provider-Enrollment-and-Certification/CertificationandComplianc/Downloads/NHC-Year-Five-Report.pdf.
159 Levinson D. Medicare Nursing Home Resident Hospitalization Rates Merit Additional Monitoring. OEI-06-11-00040. Centers for Medicare & Medicaid Services. Baltimore MD. November. 2013. http://oig.hhs.gov/oei/reports/oei-06-11-00040.pdf.
160 Centers for Medicare & Medicaid Services. Medicare nursing home compare Technical Users Guide on Staffing. Centers for Medicare & Medicaid Services. Baltimore MD. https://www.medicare.gov/NursingHomeCompare/About/Staffing-Info.html.
161 Dabney BW, Kalisch BJ. Nurse Staffing Levels and Patient-Reported Missed Nursing Care. J Nurs Care Qual. Oct–Dec. 2015;30(4):306-12. [pmid: 25929314].
162 Kalisch BJ. Missed nursing care: a qualitative study. J Nurs Care Qual. Oct–Dec. 2006;21(4):306-13. quiz 14–5. [pmid: 16985399].
163 Simmons SF, Durkin DW, Rahman AN, et al. Resident characteristics related to the lack of morning care provision in long-term care. Gerontologist. Feb. 2013;53(1):151-61. [pmid: 22565494].
164 Schnelle JF, Osterweil D, Simmons SF. Improving the quality of nursing home care and medical-record accuracy with direct observational technologies. Gerontologist. Oct. 2005;45(5):576-82. [pmid: 16199391].
165 Simmons SF, Schnelle JF. A continuous quality improvement pilot study: impact on nutritional care quality. J Am Med Dir Assoc. Oct. 2006;7(8):480-5. [pmid: 17027624].
166 Schnelle JF, Bertrand R, Hurd D, et al. Resident choice and the survey process: the need for standardized observation and transparency. Gerontologist. Aug. 2009;49(4):517-24. [pmid: 19435928].
167 Schnelle JF, Bertrand R, Hurd D, et al. The importance of standardized observations to evaluate nutritional care quality in the survey process. J Am Med Dir Assoc. Oct. 2009;10(8):568-74. [pmid: 19808155].
168 Simmons SF, Durkin DW, Shotwell MS, et al. A staff training and management intervention in VA long-term care: impact on feeding assistance care quality. Transl Behav Med. Jun. 2013;3(2):189-99. [pmid: 24073169].
169 Goldenhar LM, Brady PW, Sutcliffe KM, et al. Huddling for high reliability and situation awareness. BMJ Qual Saf. Nov. 2013;22(11):899-906. [pmid: 23744537].
170 Wilson KA, Burke CS, Priest HA, et al. Promoting health care safety through training high reliability teams. Qual Saf Health Care. Aug. 2005;14(4):303-9. [pmid: 16076797].
171 Madsen P, Desai V, Roberts K, Wong D. Mitigating hazards through continuing design: The birth and evolution of a pediatric intensive care unit. Organization Science. 2006;17(2):239-48.
172 Simmons SF, Lim B, Schnelle JF. Accuracy of minimum data set in identifying residents at risk for undernutrition: oral intake and food complaints. J Am Med Dir Assoc. May–Jun. 2002;3(3):140-5. [pmid: 12807657].
173 Simmons SF, Peterson EN, You C. The accuracy of monthly weight assessments in nursing homes: implications for the identification of weight loss. J Nutr Health Aging. Mar. 2009;13(3):284-8. [pmid: 19262969].
174 Cadogan MP, Schnelle JF, Yamamoto-Mitani N, et al. A minimum data set prevalence of pain quality indicator: is it accurate and does it reflect differences in care processes?. J Gerontol A Biol Sci Med Sci. Mar. 2004;59(3):281-5. [pmid: 15031314].
175 Simmons SF, Cadogan MP, Cabrera GR, et al. The minimum data set depression quality indicator: does it reflect differences in care processes?. Gerontologist. Aug. 2004;44(4):554-64. [pmid: 15331813].
176 Lund BC, Schroeder MC, Middendorff G, et al. Effect of hospitalization on inappropriate prescribing in elderly Medicare beneficiaries. J Am Geriatr Soc. Apr. 2015;63(4):699-707. [pmid: 25855518].
177 Oyarzun-Gonzalez XA, Taylor KC, Myers SR, et al. Cognitive decline and polypharmacy in an elderly population. J Am Geriatr Soc. Feb. 2015;63(2):397-9. [pmid: 25688619].
178 Hein C, Forgues A, Piau A, et al. Impact of polypharmacy on occurrence of delirium in elderly emergency patients. J Am Med Dir Assoc. 2014;15(11):850 e11-5. [pmid: 25405712].
179 Kashyap M, Tu le M, Tannenbaum C. Prevalence of commonly prescribed medications potentially contributing to urinary symptoms in a cohort of older patients seeking care for incontinence. BMC Geriatr. 2013;13:57. [pmid: 23758756].
180 Jyrkka J, Enlund H, Lavikainen P, et al. Association of polypharmacy with nutritional status, functional ability and cognitive capacity over a three-year period in an elderly population. Pharmacoepidemiol Drug Saf. May. 2011;20(5):514-22. [pmid: 21308855].
181 MetLife Market Institute. MetLife Market Survey of Nursing Homes, Assisted Living, Adult Day Services and Home Care Costs. Westport, CT. 2011. https://www.metlife.com/assets/cao/mmi/publications/studies/2011/mmi-market-survey-nursing-home-assisted-living-adult-day-services-costs.pdf.
182 National Center for Health Statistics. Residents Living in Residential Care Facilities: United States, 2010 National Center for Health Statistics. 2012. http://www.cdc.gov/nchs/data/databriefs/db91.htm.
183 Sloane PD, Zimmerman S, Gruber-Baldini AL, et al. Health and functional outcomes and health care utilization of persons with dementia in residential care and assisted living facilities: comparison with nursing homes. Gerontologist. Oct. 2005;45 Spec No 1(1):124-32. [pmid: 16230759].
184 Zimmerman S, Sloane PD, Williams CS, et al. Dementia care and quality of life in assisted living and nursing homes. Gerontologist. Oct. 2005;45 Spec No 1(1):133-46. [pmid: 16230760].
185 Frytak JR, Kane RA, Finch MD, et al. Outcome trajectories for assisted living and nursing facility residents in Oregon. Health Serv Res. Apr. 2001;36(1 Pt 1):91-111. [pmid: 11324746].