# Methods

We used discussions with Key Informants and targeted searches of the published literature to identify resident safety issues and contextual factors related to safety in this setting. We used published systematic reviews, narrative reviews, meta-analyses, and primary and secondary research studies to address Guiding Questions (GQs) 1, 2, and 4.

For GQ3, we identified existing systematic reviews via literature searches described below and supplemented the studies presented in each selected review with a tabulation of new prospective comparative intervention studies published since the most recent review’s conduct.

## Data Collection

### Discussions With Key Informants

In consultation with the investigative team and the Agency for Healthcare Research and Quality (AHRQ), we assembled a list of individuals representing perspectives including nursing home safety, hospital safety, quality of care, assisted living administration, health services research, advocacy, policy, medication safety, and risk management. Seven of 20 invited individuals agreed to participate in three calls (details in Appendix A). Participants included a representative from the Centers for Medicare & Medicaid Services (CMS); the Administration for Community Living, academic researchers; the long-term care industry; and clinicians with expertise in nursing home staffing, nursing home and long-term care, organizational culture and workforce development, quality of care, patient-reported outcomes in nursing homes, outcomes in the frail older adults, and health care epidemiology and infection control.

### Published Literature Search

We used a combination of controlled vocabulary terms and keywords to search the published literature for systematic reviews and studies that specifically evaluated interventions addressing the key safety areas identified above. Thus, other types of studies (e.g., descriptive, cross-sectional) were excluded from our review even if focused on the key safety areas. We used two primary search strategies for GQ3:

1. We searched MEDLINE and the Cumulative Index of Nursing and Allied Health Literature (CINAHL) using controlled and key terms for concepts including nursing home, long-term care, older adults, and the outcome areas (e.g., pressure ulcers, falls, infection) of interest, as well as related broad terms and descriptors. Our search strategies for this GQ focused specifically on the nursing home setting and the outcome areas of interest. We sought to identify recent existing systematic reviews and newly published literature. We searched these databases from 2005 to October 2015. We selected the 2005 start date to capture more recent literature published since the implementation of Nursing Home Compare in 1998 and the introduction of the CMS Five-Star quality rating in 2008.
2. We also updated the searches used in a sample of the systematic reviews we identified for GQ3 from the end search date of each selected review forward in order to identify newly published literature.

We present the literature search details in Appendix B.

## Screening of Studies for GQ3

We screened the included literature for systematic reviews and publications that addressed one or more GQs. Two investigators independently screened the full text of each publication identified in the literature search using the criteria outlined in Table 2. Any discrepancies between investigators were resolved via discussion to reach consensus or via a senior investigator. We used a simple categorization scheme to code the reasons for exclusion from GQ3. We used EndNote® to record and track the disposition of references identified.

Table 2 Inclusion criteria for evaluation studies

Category | Criteria
Study Population | Residents in nursing home facilities (short stay and long stay)
Publication Languages | English only
Timeframe | 2005 to the present
Admissible Evidence | [underlined: Study Design] Systematic Reviews, Meta-analyses, Randomized controlled trials, Prospective intervention studies, including cohorts with comparison groups, and Pre-post studies [underlined: Safety Outcomes Per Agency for Healthcare Research and Quality Common Format] Falls with injury Pressure ulcers Infection, including healthcare-associated infection, urinary tract infection, and antibiotic stewardship Medication errors and adverse drug events (e.g., delirium), including inappropriate medication use and polypharmacy

## Quality Assessment for GQ3

We used the Risk of Bias in Systematic Reviews (ROBIS) tool18 to assess the overall risk of bias of the included systematic reviews. As noted previously, we outlined reviews but we did not assess individual studies. The ROBIS tool is designed to assess relevance, potential for bias in the study eligibility criteria, identification and selection of studies, data collection and study appraisal, and synthesis and findings. One reviewer completed an assessment for each review after all reviewers initially completed scoring of the same set of test reviews in order to compare ratings and discuss any areas of discrepancy.

## Data Organization and Presentation

We summarize information extracted from the published literature in the results and discussion sections of this report. We identified resident safety themes and contextual issues from expert input and the published literature and Key Informant discussions for GQ1 and GQ2. For GQ3, we provide an overview of existing systematic reviews and original research published since the end date of the systematic reviews. In addition to describing the available systematic reviews, we catalogued the numbers and designs of newer studies that could potentially inform the assessment of interventions for each of the resident safety outcomes identified in Table 3.

## Peer Review

A draft of this Technical Brief was posted to the AHRQ Web site for 4 weeks for public comments. During this time, the Scientific Resource Center (SRC) distributed the draft report to individuals who agreed to serve as peer reviewers. The SRC collected the feedback from peer reviewers and forwarded the compiled comments to report authors. We reviewed the comments and made appropriate changes to the final report. We documented the report revisions and provided a summary of responses to the individual comments received from public and peer reviewers in a disposition of comments table. The disposition of comments table will be available on the AHRQ Web site after publication of the final Technical Brief Report.