# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Barbara J. Bowers, R.N., Ph.D., FAAN^*^
  * Provided input on draft report.
  School of Nursing
  University of Wisconsin–Madison
  Madison, WI
- Charlene A. Harrington, R.N., Ph.D.^*^
  Professor Emeritus, Sociology and Nursing
  University of California
  San Francisco, CA
- Vincent Mor, Ph.D.
  Brown University
  Providence Veterans Administration Medical Center
  Providence, RI
- Ed Mortimore, Ph.D.
  Centers for Medicare & Medicaid Services
  Division of Nursing Homes
  Baltimore, MD
- Beverly Sanborn
  Belmont Village Senior Living
  Nashville, TN
- Thomas Talbot, M.D., M.P.H.^*^
  Vanderbilt University School of Medicine
  Nashville, TN
- Jane Tilly, Dr.P.H., M.P.A.^*^
  United States Administration for Community Living/Administration on Aging
  Washington, DC