# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project. Ms. Katie Worley managed the project and helped with data collection and analysis. Drs. Shanthi Krishnaswami and Mamata Raj assessed reviews. Ms. Jessica Kimber and Ms. Sanura Latham helped with retrieving studies and creating tables. We also thank our Task Order Officer for her invaluable input throughout the project.