# Background

## Nursing Home Safety

The Agency for Healthcare Research and Quality (AHRQ) defines safety as “a type of process or structure that reduces the probability of an adverse event.”1 An adverse event is defined as harm to a resident as a result of medical care or in a health care setting.2 Studying adverse events and interventions that may prevent them and/or promote safety is an important but complex undertaking, particularly in settings with vulnerable populations (typically, but not exclusively, defined as elders, people with economic disadvantages, the uninsured, low-income children, the homeless, racial and ethnic minorities, and those with chronic health conditions).3–5

Nursing home residents are susceptible to adverse outcomes, including patient safety events, for a number of reasons. These reasons include a highly vulnerable population that is chronically frail and cognitively and or physically impaired. They often arrive debilitated and deconditioned after hospitalization for acute illness. This level of debilitation and impairment makes residents particularly vulnerable during transitions in care between providers and settings. Because of the uniqueness of the nursing home setting and its population, studying the effectiveness of safety interventions in the nursing home is critically important.

Deficiencies in care provided in nursing homes are reported through programs, including the Centers for Medicare & Medicaid Services (CMS) Nursing Home Compare system, a publicly accessible database of quality of care-related information that compiles data from Medicaid- and Medicare-certified nursing homes. In 2014, an average of 7.96 deficiencies in care per nursing home was reported in State surveys. The most common deficiencies were for failures in infection control, environmental safety, food sanitation, quality of care, and unnecessary medication use. Not all deficiencies are associated with safety issues; however, over 20 percent of facilities had a deficiency for actual harm or jeopardy, which would constitute a safety issue. An estimated mean 1.5 falls/bed/year occur in long-term care facilities, with 4 percent of these resulting in fracture and 11 percent resulting in serious injuries such as lacerations and head trauma.6, 7 Additionally, Federal deficiency data from 2012 (Table 1) demonstrate an average of 6.1 deficiency citations per facility. These data may include both short and long-term care residents (Table 1). Specific to short-stay residents, one in five older adults admitted to skilled nursing facilities (SNFs) after hospitalization experiences adverse events, and 60 percent of these are preventable.2 Per the 2014 Office of the Inspector General (OIG) report, Adverse Events in Skilled Nursing Facilities: National Incidence Among Medicare Beneficiaries, among the 10 percent of residents harmed by adverse events, half were readmitted to the hospital for treatment, resulting in $2.8 billion in Medicare spending.2

Table 1 Facility characteristics

Facility Characteristics^*^ (n=15,683 Nursing Homes) | Proportion Nationwide
Percent dually certified (Medicare and Medicaid) | 91.4%
Average occupancy rate | 82.7%
Percent 50–99 beds | 36.5%
Percent 100–199 beds | 44.1%
Percent for-profit status | 69.0%
Average total staffing hours per resident per day (HPRD) | 4.12
Average licensed nurse staffing (HPRD) | 1.67
Average nurse aide staffing Level (HPRD) | 2.45
Average number of health deficiency citations per facility | 6.1
Percent with citations for immediate jeopardy or actual harm | 3.4%
Percent with citations for substandard quality of care | 3.4%
Percent with citation for use of restraints | 6.0%
Percent with deficiency for failure to treat/prevent pressure ulcers | 14.6%

* Based on Centers for Medicare & Medicaid Services data for 15,683 nursing homes, Nursing Home Data Compendium 2012 Edition.8 Staffing Data reflect 2015 national average based on medicare.gov/nursinghomecompare.

Licensed Staff comprises Licensed Vocational Nurse (LVN), Licensed Practical Nurse (LPN), and Registered Nurse (RN).

HPRD=Hours per resident per day.

## Technical Brief Objectives

The goals of this Technical Brief are to describe the state of the literature focusing on interventions that address safety in the nursing home setting, to identify gaps and in so doing, to provide a research agenda for future work. A Technical Brief is not intended to be a systematic review and thus does not summarize results or conclusions of existing research. Rather, it should provide the reader with an overview of available data and perspective around a given clinical intervention or issues in an area of care.

Because of the breadth of literature on this topic, we describe the availability of systematic reviews rather than primary studies. In addition, we provide an estimate of the number of new studies addressing nursing home safety practices in key areas of interest published after these systematic reviews that could potentially be available for an update. Finally, we also engaged stakeholders to augment the findings from the literature and inform the summary of contextual issues unique to the nursing home setting, barriers to implementation and/or broad uptake of safety-related interventions, and future areas of research.

## Report Organization

We have organized the report by Guiding Questions (GQs) and summarized relevant literature and Key Informant perspectives. GQ1, GQ2, and GQ4 reflect information found in published and unpublished literature, including opinion pieces and general materials. They also include the perspectives of our Key Informants.

GQ3 is limited to a high-level evidence map of systematic reviews and empirical studies. Thus, GQ1 and GQ2 describe issues of relevance, while GQ3 identifies empirical literature on those issues. GQ4 then addresses areas in which future research is needed based on the current state of the science.

The following GQs provide the structure for this Technical Brief.

GQ1 Describe interventions for resident safety practices in nursing home settings
  GQ1a What are the safety issues of particular concern in the nursing home setting?
  GQ1b Are there important differences in safety issues for short-stay versus long-stay residents?
  GQ1c Are there specific interventions that have improved patient safety in the hospital setting that could transfer to the nursing home setting, but have yet to be tested as such?
GQ2 Describe the context in which interventions are used for safety practices in nursing home settings
  GQ2a What characteristics and qualities of nursing homes and nursing home residents create unique settings for assessing safety and may affect choice of intervention and success rates? Considerations include:
    a. Staffing – type, education, numbers, turnover
    b. Particular vulnerability of the residents
    c. Resident mix, including short and long stay
GQ3 Describe current literature assessing interventions for improving safety practices in nursing home settings
  GQ3a What is the state of the current research based on the following criteria:
    a. Indication/resident inclusion criteria
    b. Type of intervention
    c. Study design/size
    d. Comparator
    e. Outcomes
GQ4 Identify the important issues raised by interventions for safety practices in nursing home settings
  GQ4a What is the uptake of evidence-based nursing home interventions beyond individual test sites? What are the most important barriers/facilitators to uptake of successful interventions?
  GQ4b What major areas for future research remain regarding resident safety in nursing homes?
  GQ4c In what ways is the field of long-term care changing such that resident safety interventions may need to adapt to a new environment, and what additional challenges do these changing conditions bring to increasing long-term care resident safety?

## Scope

AHRQ has developed a Common Format for reporting safety events in nursing homes that focuses on four safety issues that served as the starting point for this report. Those events are: falls with injury, infection, pressure ulcers, and medication errors. However, studies of other undesired outcomes or lapses in care beyond these safety events (e.g., health and safety deficiencies identified by surveyors) point to the link between adverse events and what we term “potentially contributing events” (see GQ4).9–16 In practice, interventions to prevent the safety events identified in the Common Format are likely to prevent other negative outcomes as well since many interventions focused on the common format events are multifaceted. For example, pressure ulcer interventions often address incontinence care and nutrition since these are primary risk factors for pressure ulcer development. We also note that weight loss in nursing homes has been recently endorsed by the National Quality Forum as a long-term care safety indicator.17

While the presumptive link between the four safety events and other negative outcomes has some face validity, the mechanism of causality is not well understood. We address this gap in understanding in our discussion of future research needs (GQ4).