# Comparative Studies of Interventions Addressing Common Format Safety Events in the Nursing Home Published After the Publication of Systematic Reviews Included in This Technical Brief

## Falls

1 Kennedy CC, Ioannidis G, Thabane L, Adachi JD, Marr S, Giangregorio LM, Morin SN, Crilly RG, Josse RG, Lohfeld L, Pickard LE, van der Horst ML, Campbell G, Stroud J, Dolovich L, Sawka AM, Jain R, Nash L, Papaioannou A. Successful knowledge translation intervention in long-term care: final results from the vitamin D and osteoporosis study (ViDOS) pilot cluster randomized controlled trial. Trials. 2015;16:214-24. [pmid: 25962885].
2 Sackley CM, Walker MF, Burton CR, Watkins CL, Mant J, Roalfe AK, Wheatley K, Sheehan B, Sharp L, Stant KE, Fletcher-Smith J, Steel K, Wilde K, Irvine L, Peryer G. An occupational therapy intervention for residents with stroke related disabilities in UK care homes (OTCH): cluster randomised controlled trial. BMJ. 2015;350:h468. [pmid: 25657106].
3 Greenspan SL, Perera S, Ferchak MA, Nace DA, Resnick NM. Efficacy and safety of single-dose zoledronic Acid for osteoporosis in frail elderly women: a randomized clinical trial. JAMA Internal Medicine. 2015;175:913-21. [pmid: 25867538].
4 Gregersen M, Borris LC, Damsgaard EM. Postoperative blood transfusion strategy in frail, anemic elderly patients with hip fracture: the TRIFE randomized controlled trial. Acta Orthop. 2015;86:363-72. [pmid: 25586270].
5 Husebo BS, Ostelo R, Strand LI. The MOBID-2 pain scale: reliability and responsiveness to pain in patients with dementia. European journal of pain. 2014;18(10):1419-30. [pmid: 24799157].
6 Frankenthal D, Lerman Y, Kalendaryev E, Lerman Y. Intervention with the screening tool of older persons potentially inappropriate prescriptions/screening tool to alert doctors to right treatment criteria in elderly residents of a chronic geriatric facility: a randomized clinical trial. Journal of the American Geriatrics Society. 2014;62(9):1658-65. [pmid: 25243680].
7 da Silva Borges EG, de Souza Vale RG, Cader SA, Leal S, Miguel F, Pernambuco CS, Dantas EH. Postural balance and falls in elderly nursing home residents enrolled in a ballroom dancing program. Archives of gerontology and geriatrics. 2014;59(2):312-6. [pmid: 24845606].
8 Galik E, Resnick B, Hammersla M, Brightwater J. Optimizing function and physical activity among nursing home residents with dementia: testing the impact of function-focused care. Gerontologist. 2014;54(6):930-43. [pmid: 24092822].
9 Alvarez-Barbosa F, del Pozo-Cruz J, del Pozo-Cruz B, Alfonso-Rosa RM, Rogers ME, Zhang Y. Effects of supervised whole body vibration exercise on fall risk factors, functional dependence and health-related quality of life in nursing home residents aged 80+. Maturitas. 2014;79(4):456-63. [pmid: 25449826].
10 Buckinx F, Beaudart C, Maquet D, Demonceau M, Crielaard JM, Reginster JY, Bruyere O. Evaluation of the impact of 6-month training by whole body vibration on the risk of falls among nursing home residents, observed over a 12-month period: a single blind, randomized controlled trial. Aging clinical and experimental research. 2014;26(4):369-76. [pmid: 24469903].
11 van de Ven G, Draskovic I, van Herpen E, Koopmans RT, Donders R, Zuidema SU, Adang EM, Vernooij-Dassen MJ. The economics of dementia-care mapping in nursing homes: a cluster-randomised controlled trial. PLoS ONE [Electronic Resource]. 2014;9(1):e86662.
12 Meguro K, Ouchi Y, Akanuma K, Meguro M, Kasai M. Donepezil can improve daily activities and promote rehabilitation for severe Alzheimer’s patients in long-term care health facilities. BMC Neurology. 2014;14:243. [pmid: 25516360].
13 Buckinx F, Beaudart C, Maquet D, Demonceau M, Crielaard JM, Reginster JY, Bruyere O. Evaluation of the impact of 6-month training by whole body vibration on the risk of falls among nursing home residents, observed over a 12-month period: a single blind, randomized controlled trial. Aging Clin Exp Res. 2014;26:369-76. [pmid: 24469903].
14 Beaudart C, Maquet D, Mannarino M, Buckinx F, Demonceau M, Crielaard JM, Reginster JY, Bruyere O. Effects of 3 months of short sessions of controlled whole body vibrations on the risk of falls among nursing home residents. BMC Geriatrics. 2013;13:42. [pmid: 23647914].
15 Colon-Emeric CS, McConnell E, Pinheiro SO, Corazzini K, Porter K, Earp KM, Landerman L, Beales J, Lipscomb J, Hancock K, Anderson RA. CONNECT for better fall prevention in nursing homes: results from a pilot intervention study. Journal of the American Geriatrics Society. 2013;61(12):2150-9. [pmid: 24279686].
16 Kovacs E, Sztruhar Jonasne I, Karoczi CK, Korpos A, Gondos T. Effects of a multimodal exercise program on balance, functional mobility and fall risk in older adults with cognitive impairment: a randomized controlled single-blind study. European journal of physical and rehabilitation medicine. 2013;49(5):639-48. [pmid: 23820879].
17 Tuunainen E, Rasku J, Jantti P, Moisio-Vilenius P, Makinen E, Toppila E, Pyykko I. Postural stability and quality of life after guided and self-training among older adults residing in an institutional setting. Clinical interventions in aging. 2013;8:1237-46. [pmid: 24072969].
18 Teresi JA, Ramirez M, Remler D, Ellis J, Boratgis G, Silver S, Lindsey M, Kong J, Eimicke JP, Dichter E. Comparative effectiveness of implementing evidence-based education and best practices in nursing homes: effects on falls, quality-of-life and societal costs. International journal of nursing studies. 2013;50(4):448-63. [pmid: 21807366].
19 Underwood M, Lamb SE, Eldridge S, Sheehan B, Slowther A, Spencer A, Thorogood M, Atherton N, Bremner SA, Devine A, Diaz-Ordaz K, Ellard DR, Potter R, Spanjers K, Taylor SJ. Exercise for depression in care home residents: a randomised controlled trial with cost-effectiveness analysis (OPERA). Health technology assessment. 2013;17(18):1-281. [pmid: 23632142].
20 Snider KT, Snider EJ, Johnson JC, Hagan C, Schoenwald C. Preventative osteopathic manipulative treatment and the elderly nursing home resident: a pilot study. Journal of the American Osteopathic Association. 2012;112(8):489-501. [pmid: 22904246].
21 Gusi N, Carmelo Adsuar J, Corzo H, Del Pozo-Cruz B, Olivares PR, Parraca JA. Balance training reduces fear of falling and improves dynamic balance and isometric strength in institutionalised older people: a randomised trial. Journal of physiotherapy. 2012;58(2):97-104. [pmid: 22613239].
22 Kopke S, Muhlhauser I, Gerlach A, Haut A, Haastert B, Mohler R, Meyer G. Effect of a guideline-based multicomponent intervention on use of physical restraints in nursing homes: a randomized controlled trial. JAMA. 2012;307(20):2177-84. [pmid: 22618925].
23 Gruber-Baldini L, Resnick B, Hebel JR, Galik E, Zimmerman S. Adverse events associated with the Res-Care Intervention. Journal of the American Medical Directors Association. 2011;12(8):584-9. [pmid: 21450187].
24 Klages K, Zecevic A, Orange JB, Hobson S. Potential of Snoezelen room multisensory stimulation to improve balance in individuals with dementia: a feasibility randomized controlled trial. Clinical Rehabilitation. 2011;25(7):607-16. [pmid: 21382864].
25 Gulpers MJ, Bleijlevens MH, Ambergen T, Capezuti E, van Rossum E, Hamers JP. Belt restraint reduction in nursing homes: effects of a multicomponent intervention program. Journal of the American Geriatrics Society. 2011;59(11):2029-36. [pmid: 22092189].
26 Koczy P, Becker C, Rapp K, Klie T, Beische D, Buchele G, Kleiner A, Guerra V, Rissmann U, Kurrle S, Bredthauer D. Effectiveness of a multifactorial intervention to reduce physical restraints in nursing home residents. Journal of the American Geriatrics Society. 2011;59(2):333-9. [pmid: 21314651].
27 Cakar E, Dincer U, Kiralp MZ, Cakar DB, Durmus O, Kilac H, Soydan FC, Sevinc S, Alper C. Jumping combined exercise programs reduce fall risk and improve balance and life quality of elderly people who live in a long-term care facility. European journal of physical and rehabilitation medicine. 2010;46(1):59-67. [pmid: 20332728].
28 Rapp K, Lamb SE, Erhardt-Beer L, Lindemann U, Rissmann U, Klenk J, Becker C. Effect of a statewide fall prevention program on incidence of femoral fractures in residents of long-term care facilities. Journal of the American Geriatrics Society. 2010;58(1):70-5. [pmid: 20002505].
29 Fitzgerald TG, Hadjistavropoulos T, MacNab YC. Caregiver fear of falling and functional ability among seniors residing in long-term care facilities. Gerontology. 2009;55(4):460-7. [pmid: 19468202].
30 Bouwen, De Lepeleire J, Buntinx F. Rate of accidental falls in institutionalised older people with and without cognitive impairment halved as a result of a staff-oriented intervention. Age and ageing. 2008;37(3):306-10. [pmid: 18385186].
31 Uy, Kurrle SE, Cameron ID. Inpatient multidisciplinary rehabilitation after hip fracture for residents of nursing homes: a randomised trial. Australasian journal on ageing. 2008;27(1):43-4. [pmid: 18713215].
32 Bentzen H, Bergland A, Forsen L. Risk of hip fractures in soft protected, hard protected, and unprotected falls. Injury prevention. 2008;14(5):306-10. [pmid: 18836047].
33 Bentzen H, Forsen L, Becker C, Bergland A. Uptake and adherence with soft- and hard-shelled hip protectors in Norwegian nursing homes: a cluster randomised trial. Osteoporosis international. 2008;19:101-11. [pmid: 17653617].
34 Holmes D, Teresi JA, Ramirez M, Ellis J, Eimicke J, Jian Kong, Orzechowska L, Silver S. An evaluation of a monitoring system intervention: falls, injuries, and affect in nursing homes. Clinical nursing research. 2007;16(4):317-35. [pmid: 17991911].
35 Capezuti E, Wagner LM, Brush BL, Boltz M, Renz S, Talerico KA. Consequences of an intervention to reduce restrictive side rail use in nursing homes. Journal of the American Geriatrics Society. 2007;55(3):334-41. [pmid: 17341234].
36 Wagner LM, Capezuti E, Taylor JA, Sattin RW, Ouslander JG. Impact of a falls menu-driven incident-reporting system on documentation and quality improvement in nursing homes. Gerontologist. 2005;45(6):835-42. [pmid: 16326667].
37 O’Halloran PD, Murray LJ, Cran GW, Dunlop L, Kernohan G, Beringer TR. The effect of type of hip protector and resident characteristics on adherence to use of hip protectors in nursing and residential homes--an exploratory study. International journal of nursing studies. 2005;42(4):387-97. [pmid: 15847901].
38 Hien le TT, Cumming RG, Cameron ID, Chen JS, Lord SR, March LM, Schwarz J, Le Couteur DG, Sambrook PN. Atypical antipsychotic medications and risk of falls in residents of aged care facilities. Journal of the American Geriatrics Society. 2005;53(8):1290-5. [pmid: 16078953].

## Pressure Ulcers

1 Cereda E, Klersy C, Serioli M, Crespi A, D’Andrea F. Group OligoElement Sore Trial Study. A nutritional formula enriched with arginine, zinc, and antioxidants for the healing of pressure ulcers: a randomized trial. Annals of Internal Medicine. 2015;162(3):167-74. [pmid: 25643304].
2 Pouyssegur V, Brocker P, Schneider SM, Philip JL, Barat P, Reichert E, Breugnon F, Brunet D, Civalleri B, Solere JP, Bensussan L, Lupi-Pegurier L. An innovative solid oral nutritional supplement to fight weight loss and anorexia: open, randomised controlled trial of efficacy in institutionalised, malnourished older adults. Age & Ageing. 2015;44(2):245-51. [pmid: 25324332].
3 Stern, Mitsakakis N, Paulden M, Alibhai S, Wong J, Tomlinson G, Brooker AS, Krahn M, Zwarenstein M. Pressure ulcer multidisciplinary teams via telemedicine: a pragmatic cluster randomized stepped wedge trial in long term care. BMC Health Services Research. 2014;14:83. [pmid: 24559218].
4 Bergstrom N, Horn SD, Rapp M, Stern A, Barrett R, Watkiss M, Krahn M. Preventing Pressure Ulcers: A Multisite Randomized Controlled Trial in Nursing Homes. Ont Health Technol Assess Ser. 2014;14:1-32.
5 Beeckman D, Clays E, Van Hecke A, Vanderwee K, Schoonhoven L, Verhaeghe S. A multi-faceted tailored strategy to implement an electronic clinical decision support system for pressure ulcer prevention in nursing homes: a two-armed randomized controlled trial. International journal of nursing studies. 2013;50(4):475-86. [pmid: 23036149].
6 Sakae K, Agata T, Kamide R, Yanagisawa H. Effects of L-carnosine and its zinc complex (Polaprezinc) on pressure ulcer healing. Nutrition in clinical practice. 2013;28(5):609-16. [pmid: 23835365].
7 van Leen M, Hovius S, Halfens R, Neyens J, Schols J. Pressure relief with visco-elastic foam or with combined static air overlay? A prospective, crossover randomized clinical trial in a dutch nursing home. Wounds. 2013;25(10):287-92. [pmid: 25867519].
8 Bergstrom N, Horn SD, Rapp MP, Stern A, Barrett R, Watkiss M. Turning for Ulcer ReductioN: a multisite randomized clinical trial in nursing homes. Journal of the American Geriatrics Society. 2013;61(10):1705-13. [pmid: 24050454].
9 Yap TL, Kennerly SM, Simmons MR, Buncher CR, Miller E, Kim J, Yap WY. Multidimensional team-based intervention using musical cues to reduce odds of facility-acquired pressure ulcers in long-term care: a paired randomized intervention study. Journal of the American Geriatrics Society. 2013;61(9):1552-9. [pmid: 24028358].
10 Moore Z, Cowman S, Posnett J. An economic analysis of repositioning for the prevention of pressure ulcers. Journal of Clinical Nursing. 2013;22(15–16):2354-60. [pmid: 23829408].
11 Beeckman D, Clays E, Van Hecke A, Vanderwee K, Schoonhoven L, Verhaeghe S. A multi-faceted tailored strategy to implement an electronic clinical decision support system for pressure ulcer prevention in nursing homes: a two-armed randomized controlled trial. Int J Nurs Stud. 2013;50:475-86. [pmid: 23036149].
12 Fossum M, Ehnfors M, Svensson E, Hansen LM, Ehrenberg A. Effects of a computerized decision support system on care planning for pressure ulcers and malnutrition in nursing homes: an intervention study. Int J Med Inform. 2013;82:911-21. [pmid: 23827767].
13 Bergstrom N, Horn SD, Rapp MP, Stern A, Barrett R, Watkiss M. Turning for Ulcer ReductioN: a multisite randomized clinical trial in nursing homes. J Am Geriatr Soc. 2013;61:1705-13. [pmid: 24050454].
14 Twersky J, Montgomery T, Sloane R, Weiner M, Doyle S, Mathur K, Francis M, Schmader K. A randomized, controlled study to assess the effect of silk-like textiles and high-absorbency adult incontinence briefs on pressure ulcer prevention. Ostomy Wound Management. 2012;58(12):18-24.
15 Lam K, Lau KK, So KK, Tam CK, Wu YM, Cheung G, Liang KS, Yeung KM, Lam KY, Yui S, Leung C. Can botulinum toxin decrease carer burden in long term care residents with upper limb spasticity? A randomized controlled study. Journal of the American Medical Directors Association. 2012;13(5):477-84. [pmid: 22521630].
16 Rantz MJ, Zwygart-Stauffacher M, Hicks L, Mehr D, Flesner M, Petroski GF, Madsen RW, Scott-Cawiezell J. Randomized multilevel intervention to improve outcomes of residents in nursing homes in need of improvement. Journal of the American Medical Directors Association. 2012;13(1):60-8. [pmid: 21816681].
17 Shannon RJ, Brown L, Chakravarthy D. Pressure Ulcer Prevention Program Study: a randomized, controlled prospective comparative value evaluation of 2 pressure ulcer prevention strategies in nursing and rehabilitation centers. Advances in Skin and Wound Care. 2012;25(10):450-64. [pmid: 22990343].
18 Kwong EW, Lau AT, Lee RL, Kwan RY. A pressure ulcer prevention programme specially designed for nursing homes: does it work?. Journal of Clinical Nursing. 2011;20(19–20):2777-86. [pmid: 21854474].
19 van Leen M, Hovius S, Neyens J, Halfens R, Schols J. Pressure relief, cold foam or static air? A single center, prospective, controlled randomized clinical trial in a Dutch nursing home. Journal of Tissue Viability. 2011;20(1):30-4. [pmid: 20510611].
20 Brienza D, Kelsey S, Karg P, Allegretti A, Olson M, Schmeler M, Zanca J, Geyer MJ, Kusturiss M, Holm M. A randomized clinical trial on preventing pressure ulcers with wheelchair seat cushions. Journal of the American Geriatrics Society. 2010;58(12):2308-14. [pmid: 21070197].
21 Mistiaen P, Achterberg W, Ament A, Halfens R, Huizinga J, Montgomery K, Post H, Spreeuwenberg P, Francke AL. The effectiveness of the Australian Medical Sheepskin for the prevention of pressure ulcers in somatic nursing home patients: a prospective multicenter randomized-controlled trial. Wound repair and regeneration. 2010;18(6):572-9. [pmid: 20946141].
22 Stotts NA, Hopf HW, Kayser-Jones J, Chertow GM, Cooper BA, Wu HS. Increased fluid intake does not augment capacity to lay down new collagen in nursing home residents at risk for pressure ulcers: a randomized, controlled clinical trial. Wound repair and regeneration. 2009;17(6):780-8. [pmid: 19821962].
23 Duimel-Peeters G, Halfens RJG, Ambergen AW, Houwing RH, Berger MPF, Snoeckx LH. The effectiveness of massage with and without dimethyl sulfoxide in preventing pressure ulcers: a randomized, double-blind cross-over trial in patients prone to pressure ulcers. International journal of nursing studies. 2007;44(8):1285-95. [pmid: 17553503].
24 Lynn J, West J, Hausmann S, Gifford D, Nelson R, McGann P, Bergstrom N, Ryan JA. Collaborative clinical quality improvement for pressure ulcers in nursing homes. Journal of the American Geriatrics Society. 2007;55(10):1663-9. [pmid: 17714457].
25 Vanderwee K, Grypdonck MH, De Bacquer D, Defloor T. Effectiveness of turning with unequal time intervals on the incidence of pressure ulcer lesions. Journal of advanced nursing. 2007;57(1):59-68. [pmid: 17184374].
26 Al-Samarrai NR, Uman GC, Al-Samarrai T, Alessi CA. Introducing a new incontinence management system for nursing home residents. Journal of the American Medical Directors Association. 2007;8(4):253-61. [pmid: 17498610].
27 Buckland R. Evaluating two dynamic mattresses in a nursing home setting. British Journal of Nursing. 2007;16(11):S28-32. [pmid: 17577192].
28 Thomas DR, Diebold MR, Eggemeyer LM. A controlled, randomized, comparative study of a radiant heat bandage on the healing of stage 3–4 pressure ulcers: a pilot study. Journal of the American Medical Directors Association. 2005;6(1):46-9. [pmid: 15871870].
29 Stechmiller JK, Langkamp-Henken B, Childress B, Herrlinger-Garcia KA, Hudgens J, Tian L, Percival SS, Steele R. Arginine supplementation does not enhance serum nitric oxide levels in elderly nursing home residents with pressure ulcers. Biological research for nursing. 2005;6(4):289-99. [pmid: 15788738].

## Infection

1 Mody L, Krein SL, Saint SK, Min LC, Montoya A, Lansing B, McNamara SE, Symons K, Fisch J, Koo E, Rye RA, Galecki A, Kabeto MU, Fitzgerald JT, Olmsted RN, Kauffman CA, Bradley SF. A targeted infection prevention intervention in nursing home residents with indwelling devices: a randomized clinical trial. JAMA International Medicine. 2015;175(5):714-23.
2 Gregersen M, Damsgaard EM, Borris LC. Blood transfusion and risk of infection in frail elderly after hip fracture surgery: the TRIFE randomized controlled trial. European journal of orthopaedic surgery & traumatology. 2015;25(6):1031-8. [pmid: 25690514].
3 Schora DM, Boehm S, Das S, Patel PA, O’Brien J, Hines C, Burdsall D, Beaumont J, Peterson K, Fausone M, Peterson LR. Impact of Detection, Education, Research and Decolonization without Isolation in Long-term care (DERAIL) on methicillin-resistant Staphylococcus aureus colonization and transmission at 3 long-term care facilities. American Journal of Infection Control. 2014;42(10 Suppl):S269-73. [pmid: 25239721].
4 Caljouw MA, van den Hout WB, Putter H, Achterberg WP, Cools HJ, Gussekloo J. Effectiveness of cranberry capsules to prevent urinary tract infections in vulnerable older persons: a double-blind randomized placebo-controlled trial in long-term care facilities. Journal of the American Geriatrics Society. 2014;62(1):103-10. [pmid: 25180378].
5 Handeland M, Grude N, Torp T, Slimestad R. Black chokeberry juice (Aronia melanocarpa) reduces incidences of urinary tract infection among nursing home residents in the long term--a pilot study. Nutrition research. 2014;34(6):518-25. [pmid: 25026919].
6 van den Hout WB, Caljouw MA, Putter H, Cools HJ, Gussekloo J. Cost-effectiveness of cranberry capsules to prevent urinary tract infection in long-term care facilities: economic evaluation with a randomized controlled trial. Journal of the American Geriatrics Society. 2014;62(1):111-6. [pmid: 25180379].
7 Lin SY. A pilot study: fluid intake and bacteriuria in nursing home residents in southern Taiwan. Nursing Research. 2013;62(1):66-72. [pmid: 22960586].
8 Snider KT, Snider EJ, Johnson JC, Hagan C, Schoenwald C. Preventative osteopathic manipulative treatment and the elderly nursing home resident: a pilot study. Journal of the American Osteopathic Association. 2012;112(8):489-501. [pmid: 22904246].
9 Van Puyenbroeck K, Hens N, Coenen S, Michiels B, Beunckens C, Molenberghs G, Van Royen P, Verhoeven V. Efficacy of daily intake of Lactobacillus casei Shirota on respiratory symptoms and influenza vaccination immune response: a randomized, double-blind, placebo-controlled trial in healthy elderly nursing home residents. American journal of clinical nutrition. 2012;95(5):1165-71. [pmid: 22440853].
10 Ho ML, Seto WH, Wong LC, Wong TY. Effectiveness of multifaceted hand hygiene interventions in long-term care facilities in Hong Kong: a cluster-randomized controlled trial. Infection Control & Hospital Epidemiology. 2012;33(8):761-7. [pmid: 22759542].
11 Laffan M, McKenzie R, Forti J, Conklin D, Marcinko R, Shrestha R, Bellantoni M, Greenough WB. Lactoferrin for the prevention of post-antibiotic diarrhea. Journal of health, population, and nutrition. 2011;29(6):547-51.

## Medication Error/Adverse Drug Events

1 Konner F, Budnick A, Kuhnert R, Wulff I, Kalinowski S, Martus P, Drager D, Kreutz R. Interventions to address deficits of pharmacological pain management in nursing home residents - A cluster-randomized trial. European Journal of Pain. 2015;19(9):1331-41. [pmid: 25690438].
2 Frankenthal D, Lerman Y, Kalendaryev E, Lerman Y. Intervention with the screening tool of older persons potentially inappropriate prescriptions/screening tool to alert doctors to right treatment criteria in elderly residents of a chronic geriatric facility: a randomized clinical trial. Journal of the American Geriatrics Society. 2014;62(9):1658-65. [pmid: 25243680].
3 Fleet E, Gopal Rao G, Patel B, Cookson B, Charlett A, Bowman C, Davey P. Impact of implementation of a novel antimicrobial stewardship tool on antibiotic use in nursing homes: a prospective cluster randomized control pilot study. Journal of Antimicrobial Chemotherapy. 2014;69:2265-73. [pmid: 24777901].
4 Garcia-Gollarte F, Baleriola-Julvez J, Ferrero-Lopez I, Cuenllas-Diaz A, Cruz-Jentoft AJ. An educational intervention on drug use in nursing homes improves health outcomes resource utilization and reduces inappropriate drug prescription. Journal of the American Medical Directors Association. 2014;15(12):885-91. [pmid: 24895001].
5 Jodar-Sanchez F, Martin JJ, Lopez del Amo MP, Garcia L, Araujo-Santos JM, Epstein D. Cost-utility analysis of a pharmacotherapy follow-up for elderly nursing home residents in Spain. Journal of the American Geriatrics Society. 2014;62(7):1272-80. [pmid: 24891096].
6 Zimmerman S, Sloane PD, Bertrand R, Olsho LE, Beeber A, Kistler C, Hadden L, Edwards A, Weber DJ, Mitchell CM. Successfully reducing antibiotic prescribing in nursing homes. Journal of the American Geriatrics Society. 2014;62(5):907-12. [pmid: 24697789].
7 Toscani F, Di Giulio P, Villani D, Giunco F, Brunelli C, Gentile S, Finetti S, Charrier L, Monti M, van der Steen JT. Treatments and prescriptions in advanced dementia patients residing in long-term care institutions and at home. Journal of palliative medicine. 2013;16(1):31-7. [pmid: 23234299].
8 Verrue C, Mehuys E, Boussery K, Adriaens E, Remon JP, Petrovic M. A pharmacist-conducted medication review in nursing home residents: impact on the appropriateness of prescribing. Acta clinica Belgica. 2012;67(6):423-9. [pmid: 23340148].
9 Laffan M, McKenzie R, Forti J, Conklin D, Marcinko R, Shrestha R, Bellantoni M, Greenough WB. Lactoferrin for the prevention of post-antibiotic diarrhea. Journal of health, population, and nutrition. 2011;29(6):547-51.
10 Boockvar KS, Carlson LaCorte H, Giambanco V, et al. Medication reconciliation for reducing drug-discrepancy adverse events. Am J Geriatr Pharmacother. 2006;4(3):236-243. [pmid: 17062324].
11 Hutt E, Pepper GA, Vojir C, Fink R, Jones KR. Assessing the appropriateness of pain medication prescribing practices in nursing homes. Journal of the American Geriatrics Society. 2006;54(2):231-9. [pmid: 16460373].
12 Madden C, Garrett J, Busby-Whitehead J. The interface between nursing homes and emergency departments: A community effort to improve transfer of information. Acad Emerg Med. 1998;5:1123-1126. [pmid: 9835479].

## References

1 Vlaeyen E, Coussement J, Leysens G, et al. Characteristics and effectiveness of fall prevention programs in nursing homes: a systematic review and meta-analysis of randomized controlled trials. J Am Geriatr Soc. Feb. 2015;63(2):211-21. [pmid: 25641225].
2 Santesso N, Carrasco-Labra A, Brignardello-Petersen R. Hip protectors for preventing hip fractures in older people. Cochrane Database of Systematic Reviews. 2014;3:CD001255. [pmid: 24687239].
3 Cameron ID, Gillespie LD, Robertson MC, et al. Interventions for preventing falls in older people in care facilities and hospitals. Cochrane Database Syst Rev. 2012;12:Cd005465. [pmid: 23235623].
4 Anderson O, Boshier PR, Hanna GB. Interventions designed to prevent healthcare bed-related injuries in patients. Cochrane Database Syst Rev. 2011;(11):Cd008931. [pmid: 22071860].
5 Howe Tracey E, Rochester L, Neil F, et al. Exercise for improving balance in older people. Cochrane Database of Systematic Reviews. 2011;(11).
6 Sawka AM, Ismaila N, Cranney A, et al. A scoping review of strategies for the prevention of hip fracture in elderly nursing home residents. PloS one 2010. 03. 03. 2010;5(3):e9515.
7 Sawka AM, Boulos P, Beattie K, et al. Hip protectors decrease hip fracture risk in elderly nursing home residents: a Bayesian meta-analysis. Journal of clinical epidemiology 2007. 04. 23. 2007;60(4):336-44.
8 Sawka AM, Boulos P, Beattie K, et al. Do hip protectors decrease the risk of hip fracture in institutional and community-dwelling elderly? A systematic review and meta-analysis of randomized controlled trials. Osteoporosis international : a journal established as result of cooperation between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the USA 2005. 12. 01. 2005;16(12):1461-74.
9 Silva RB, Eslick GD, Duque G. Exercise for falls and fracture prevention in long term care facilities: a systematic review and meta-analysis. J Am Med Dir Assoc. Sep. 2013;14(9):685-9.e2. [pmid: 23860265].
10 Balzer K, Bremer M, Schramm S, et al. Falls prevention for the elderly. GMS Health Technol Assess. 2012;8:Doc01. [pmid: 22536299].
11 Choi M, Hector M. Effectiveness of intervention programs in preventing falls: a systematic review of recent 10 years and meta-analysis. Journal of the American Medical Directors Association. 2012;13(2):188.e13-21. [pmid: 21680249].
12 Chua GT, Wong RY. Association Between Vitamin D Dosing Regimen and Fall Prevention in Long-term Care Seniors. Can Geriatr J. Dec. 2011;14(4):93-9. [pmid: 23251320].
13 Cusimano MD, Kwok J, Spadafora K. Effectiveness of multifaceted fall-prevention programs for the elderly in residential care. Inj Prev. Apr. 2008;14(2):113-22. [pmid: 18388232].
14 Oliver D, Connelly JB, Victor CR, et al. Strategies to prevent falls and fractures in hospitals and care homes and effect of cognitive impairment: systematic review and meta-analyses. Bmj. Jan. 13. 2007;334(7584):82. [pmid: 17158580].
15 Gillespie BM, Chaboyer WP, McInnes E, et al. Repositioning for pressure ulcer prevention in adults. Cochrane Database Syst Rev. 2014;4:Cd009958. [pmid: 24700291].
16 Chou R, Dana T, Bougatsos C, et al. Pressure Ulcer Risk Assessment and Prevention: Comparative Effectiveness. 2013. May. [pmid: 23762918].
17 Saha S, Smith MEB, Totten A, et al. Pressure Ulcer Treatment Strategies: Comparative Effectiveness. 2013. May. [pmid: 23785727].
18 Sullivan N, Schoelles KM. Preventing in-facility pressure ulcers as a patient safety strategy: a systematic review. Ann Intern Med. Mar. 5. 2013;158(5 Pt 2):410-6. [pmid: 23460098].
19 Niederhauser A, VanDeusen Lukas C, Parker V, et al. Comprehensive programs for preventing pressure ulcers: a review of the literature. Adv Skin Wound Care. Apr. 2012;25(4):167-88. quiz 89–90. [pmid: 22441049].
20 Pressure ulcer prevention: an evidence-based analysis. Ont Health Technol Assess Ser. 2009;9(2):1-104. [pmid: 23074524].
21 Cullum N, Petherick E. Pressure ulcers. BMJ Clin Evid. 2008;2008. [pmid: 19450317].
22 Reddy M, Gill SS, Kalkar SR, et al. Treatment of pressure ulcers: a systematic review. JAMA. Dec. 10. 2008;300(22):2647-62. [pmid: 19066385].
23 Hughes C, Tunney M, Bradley Marie C. Infection control strategies for preventing the transmission of meticillin-resistant Staphylococcus aureus (MRSA) in nursing homes for older people. Cochrane Database of Systematic Reviews. 2013;(11).
24 Uchida M, Pogorzelska-Maziarz M, Smith PW, et al. Infection prevention in long-term care: a systematic review of randomized and nonrandomized trials. Journal of the American Geriatrics Society. 2013;61(4):602-14. [pmid: 23581914].
25 Sjögren P, Nilsson E, Forsell M, et al. A systematic review of the preventive effect of oral hygiene on pneumonia and respiratory tract infection in elderly people in hospitals and nursing homes: effect estimates and methodological quality of randomized controlled trials. Journal of the American Geriatrics Society 2008. 11. 15. 2008;56(11):2124-30.
26 Clegg A, Siddiqi N, Heaven A, et al. Interventions for preventing delirium in older people in institutional long-term care. Cochrane Database Syst Rev. 2014;1:CD009537. [pmid: 24488526].
27 Patterson Susan M, Cadogan Cathal A, Kerse N, et al. Interventions to improve the appropriate use of polypharmacy for older people. Cochrane Database of Systematic Reviews. 2014;(10).
28 Wallerstedt SM, Kindblom JM, Nylén K, et al. Medication reviews for nursing home residents to reduce mortality and hospitalization: systematic review and meta-analysis. British journal of clinical pharmacology 2014. 02. 18. 2014;78(3):488-97.
29 Alldred DP, Raynor DK, Hughes C, et al. Interventions to optimise prescribing for older people in care homes. Cochrane Database Syst Rev. 2013;2:CD009095. [pmid: 23450597].
30 Fleming A, Browne J, Byrne S. The effect of interventions to reduce potentially inappropriate antibiotic prescribing in long-term care facilities: a systematic review of randomised controlled trials. Drugs Aging. Jun. 2013;30(6):401-8. [pmid: 23444263].
31 Chhabra PT, Rattinger GB, Dutcher SK, et al. Medication reconciliation during the transition to and from long-term care settings: a systematic review. Res Social Adm Pharm. Jan–Feb. 2012;8(1):60-75. [pmid: 21511543].
32 Forsetlund L, Eike MC, Gjerberg E, et al. Effect of interventions to reduce potentially inappropriate use of drugs in nursing homes: a systematic review of randomised controlled trials. BMC Geriatr. 2011;11:16. [pmid: 21496345].
33 Marasinghe KM. Computerised clinical decision support systems to improve medication safety in long-term care homes: a systematic review. BMJ Open. 2015;5(5):e006539. [pmid: 25967986].
34 Tjia J, Velten SJ, Parsons C, et al. Studies to reduce unnecessary medication use in frail older adults: a systematic review. Drugs Aging. May. 2013;30(5):285-307. [pmid: 23475597].
35 Loganathan M, Singh S, Franklin BD, et al. Interventions to optimise prescribing in care homes: systematic review. Age Ageing. Mar. 2011;40(2):150-62. [pmid: 21262782].
36 LaMantia MA, Scheunemann LP, Viera AJ, et al. Interventions to improve transitional care between nursing homes and hospitals: a systematic review. J Am Geriatr Soc. Apr. 2010;58(4):777-82. [pmid: 20398162].