# Summary Tables of Recent Systematic Reviews Addressing Interventions for Common Format Safety Events

Table C-1 Overview of systematic reviews for falls

Table C-2 Overview of systematic reviews for pressure ulcers

Table C-3 Overview of systematic reviews for infections, including healthcare-associated infection, urinary tract infection, and antibiotic stewardship

Table C-4 Overview of systematic reviews for medication errors and adverse drug events