# Literature Search Strategies

Table B-1 PubMed literature search strings for nursing home patient safety categories

Falls | | Results
#1 | “Nursing Homes”[Mesh] OR “Long-Term Care”[Mesh] OR “Homes for the Aged”[Mesh] | 54,850
#2 | “nursing home”[tiab] OR “long-term care”[tiab] OR “residential aged care”[tiab] OR “skilled nursing facility”[tiab] OR “aged care facility”[tiab] OR “aged care facilities”[tiab] NOT medline[sb] | 2,683
#3 | #1 OR #2 | 57,529
#4 | “Accidental Falls”[Mesh] | 16,283
#5 | “fall prevention”[tiab] OR “preventing falls”[tiab] NOT medline[sb] | 313
#6 | #4 OR #5 | 16,596
#7 | #3 AND #6 | 858
#8 | ((((((“Controlled Clinical Trial” [Publication Type]) OR “Multicenter Study” [Publication Type]) OR “Randomized Controlled Trial” [Publication Type])) OR (((“randomized”[tiab] OR “cluster-randomized”[tiab] OR “RCT”[tiab]) OR ((“trial”[tiab]) AND (“controlled”[tiab] OR “clinical”[tiab]))) OR (“systematic review”[tiab] OR “systematic literature review” [tiab])))) | 879,376
#9 | #7 AND #8 | 148
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 106
Pressure Ulcer | | Results
#1 | “Nursing Homes”[Mesh] OR “Long-Term Care”[Mesh] OR “Homes for the Aged”[Mesh] | 54,850
#2 | “nursing home”[tiab] OR “long-term care”[tiab] OR “residential aged care”[tiab] OR “skilled nursing facility”[tiab] OR “aged care facility”[tiab] OR “aged care facilities”[tiab] NOT medline[sb] | 2,683
#3 | #1 OR #2 | 57,529
#4 | “Pressure Ulcer”[Mesh] | 9,954
#5 | “pressure ulcer”[tiab] OR “decubitus ulcer”[tiab] OR “bedsore”[tiab] OR “pressure sore”[tiab] NOT medline[sb] | 442
#6 | #4 OR #5 | 10,394
#7 | #3 AND #6 | 764
#8 | ((((((“Controlled Clinical Trial” [Publication Type]) OR “Multicenter Study” [Publication Type]) OR “Randomized Controlled Trial” [Publication Type])) OR (((“randomized”[tiab] OR “cluster-randomized”[tiab] OR “RCT”[tiab]) OR ((“trial”[tiab]) AND (“controlled”[tiab] OR “clinical”[tiab]))) OR (“systematic review”[tiab] OR “systematic literature review” [tiab])))) | 879,376
#9 | #7 AND #8 | 92
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 69
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 30
#9 | #7 AND #8 | 9
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 6
Urinary Tract Infection | | Results
#1 | “Nursing Homes”[Mesh] OR “Long-Term Care”[Mesh] OR “Homes for the Aged”[Mesh] | 54,870
#2 | “nursing home”[tiab] OR “long-term care”[tiab] OR “residential aged care”[tiab] OR “skilled nursing facility”[tiab] OR “aged care facility”[tiab] OR “aged care facilities”[tiab] NOT medline[sb] | 2,670
#3 | #1 OR #2 | 57,536
#4 | (“Catheter-Related Infections”[Mesh] AND urin*) OR “urinary tract infections”[mesh:NoExp] | 32,703
#5 | “catheter-associated urinary tract infection”[tiab] OR “CAUTI”[tiab] or “UTI”[tiab] or “urinary tract infection”[tiab] NOT medline[sb] | 1,870
#6 | #4 OR #5 | 34,573
#7 | #3 AND #6 | 359
#8 | ((((((“Controlled Clinical Trial” [Publication Type]) OR “Multicenter Study” [Publication Type]) OR “Randomized Controlled Trial” [Publication Type])) OR (((“randomized”[tiab] OR “cluster-randomized”[tiab] OR “RCT”[tiab]) OR ((“trial”[tiab]) AND (“controlled”[tiab] OR “clinical”[tiab]))) OR (“systematic review”[tiab] OR “systematic literature review” [tiab])))) | 879,613
#9 | #7 AND #8 | 41
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 26
Medication error | | Results
#1 | “Nursing Homes”[Mesh] OR “Long-Term Care”[Mesh] OR “Homes for the Aged”[Mesh] | 54,870
#2 | “nursing home”[tiab] OR “long-term care”[tiab] OR “residential aged care”[tiab] OR “skilled nursing facility”[tiab] OR “aged care facility”[tiab] OR “aged care facilities”[tiab] NOT medline[sb] | 2,670
#3 | #1 OR #2 | 57,536
#4 | “Medication Errors”[Mesh] | 11,859
#5 | “medication reconciliation”[tiab] OR “medication error”[tiab] NOT medline[sb] | 279
#6 | #4 OR #5 | 12,138
#7 | #3 AND #6 | 302
#8 | ((((((“Controlled Clinical Trial” [Publication Type]) OR “Multicenter Study” [Publication Type]) OR “Randomized Controlled Trial” [Publication Type])) OR (((“randomized”[tiab] OR “cluster-randomized”[tiab] OR “RCT”[tiab]) OR ((“trial”[tiab]) AND (“controlled”[tiab] OR “clinical”[tiab]))) OR (“systematic review”[tiab] OR “systematic literature review” [tiab])))) | 879,613
#9 | #7 AND #8 | 44
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 41
Infection | | Results
#1 | “Nursing Homes”[Mesh] OR “Long-Term Care”[Mesh] OR “Homes for the Aged”[Mesh] | 54,870
#2 | “nursing home”[tiab] OR “long-term care”[tiab] OR “residential aged care”[tiab] OR “skilled nursing facility”[tiab] OR “aged care facility”[tiab] OR “aged care facilities”[tiab] NOT medline[sb] | 2,670
#3 | #1 OR #2 | 57,536
#4 | “Infectious Disease Transmission, Professional-to-Patient”[Mesh] | 1,555
#5 | “healthcare associated infection”[tiab] OR HAI[tiab] NOT medline[sb] | 327
#6 | #4 OR #5 | 1,882
#7 | #3 AND #6 | 37
#8 | ((((((“Controlled Clinical Trial” [Publication Type]) OR “Multicenter Study” [Publication Type]) OR “Randomized Controlled Trial” [Publication Type])) OR (((“randomized”[tiab] OR “cluster-randomized”[tiab] OR “RCT”[tiab]) OR ((“trial”[tiab]) AND (“controlled”[tiab] OR “clinical”[tiab]))) OR (“systematic review”[tiab] OR “systematic literature review” [tiab])))) | 879,613
#9 | #7 AND #8 | 7
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 6
Quality Improvement (system level) | | Results
#1 | “Nursing Homes”[Mesh] OR “Long-Term Care”[Mesh] OR “Homes for the Aged”[Mesh] | 54,870
#2 | “nursing home”[tiab] OR “long-term care”[tiab] OR “residential aged care”[tiab] OR “skilled nursing facility”[tiab] OR “aged care facility”[tiab] OR “aged care facilities”[tiab] NOT medline[sb] | 2,670
#3 | #1 OR #2 | 57,536
#4 | “Quality Improvement”[Mesh] OR “Quality Indicators, Health Care”[Mesh] OR “Standard of Care”[Mesh] | 21,433
#5 | “workforce training”[tiab] OR “public reporting”[tiab] OR “patient hand-off”[tiab] OR “quality improvement”[tiab] OR “reducing error”[tiab] NOT medline[sb] | 2,721
#6 | #4 OR #5 | 24,154
#7 | #3 AND #6 | 790
#8 | ((((((“Controlled Clinical Trial” [Publication Type]) OR “Multicenter Study” [Publication Type]) OR “Randomized Controlled Trial” [Publication Type])) OR (((“randomized”[tiab] OR “cluster-randomized”[tiab] OR “RCT”[tiab]) OR ((“trial”[tiab]) AND (“controlled”[tiab] OR “clinical”[tiab]))) OR (“systematic review”[tiab] OR “systematic literature review” [tiab])))) | 879,613
#9 | #7 AND #8 | 71
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 64
Medication polypharmacy/inappropriate prescribing | | Results
#1 | “Nursing Homes”[Mesh] OR “Long-Term Care”[Mesh] OR “Homes for the Aged”[Mesh] | 55,088
#2 | “nursing home”[tiab] OR “long-term care”[tiab] OR “residential aged care”[tiab] OR “skilled nursing facility”[tiab] OR “aged care facility”[tiab] OR “aged care facilities”[tiab] NOT medline[sb] | 2,901
#3 | #1 OR #2 | 57,985
#4 | (“Inappropriate Prescribing”[Mesh] OR “Polypharmacy”[Mesh] OR “Prescription Drugs”[Mesh] OR “Prescriptions”[Mesh] OR “Drug Utilization”[Mesh]) | 47,840
#5 | Polypharmacy[tiab] OR “over-prescribe”[tiab] OR “over prescribe”[tiab] “overmedicate”[tiab] OR “over medicated”[tiab] OR “overmedicated”[tiab] OR “overprescribe”[tiab] OR “medication appropriateness”[tiab] OR “multi-drug”[tiab] OR “inappropriate drug”[tiab] OR “inappropriate medication”[tiab] OR “inappropriate prescription*”[tiab] OR “drug overuse”[tiab] OR “zhan criteria”[tiab] OR “beers criteria”[tiab] NOT medline[sb] | 1,148
#6 | #4 OR #5 | 48,988
#7 | #3 AND #6 | 1,322
#8 | ((((((“Controlled Clinical Trial” [Publication Type]) OR “Multicenter Study” [Publication Type]) OR “Randomized Controlled Trial” [Publication Type])) OR (((“randomized”[tiab] OR “cluster-randomized”[tiab] OR “RCT”[tiab]) OR ((“trial”[tiab]) AND (“controlled”[tiab] OR “clinical”[tiab]))) OR (“systematic review”[tiab] OR “systematic literature review” [tiab])))) | 891,435
#9 | #7 AND #8 | 147
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 109
Resident Centered Care | | Results
#1 | “Nursing Homes”[Mesh] OR “Long-Term Care”[Mesh] OR “Homes for the Aged”[Mesh] | 55,089
#2 | “nursing home”[tiab] OR “long-term care”[tiab] OR “residential aged care”[tiab] OR “skilled nursing facility”[tiab] OR “aged care facility”[tiab] OR “aged care facilities”[tiab] NOT medline[sb] | 2,902
#3 | #1 OR #2 | 57,987
#4 | “patient-centered care”[Mesh] OR “Green House”[tiab] OR “Eden Alternative”[tiab] OR “Wellspring Innovative Solutions”[tiab] OR “Planetree”[tiab] | 12432
#5 | “Culture change”[tiab] OR “individualized care”[tiab] OR “resident centered”[tiab] OR “person-directed”[tiab] OR “resident-directed”[tiab] OR “Person-centered”[tiab] OR “Resident-centered”[tiab] OR “Person-centered”[tiab] NOT medline[sb] | 530
#6 | #4 OR #5 | 12,962
#7 | #3 AND #6 | 470
#8 | ((((((“Controlled Clinical Trial” [Publication Type]) OR “Multicenter Study” [Publication Type]) OR “Randomized Controlled Trial” [Publication Type])) OR (((“randomized”[tiab] OR “cluster-randomized”[tiab] OR “RCT”[tiab]) OR ((“trial”[tiab]) AND (“controlled”[tiab] OR “clinical”[tiab]))) OR (“systematic review”[tiab] OR “systematic literature review” [tiab])))) | 891,706
#9 | #7 AND #8 | 46
#10 | #9 AND (“2005/01/01”[Date - Publication] : “3000”[Date - Publication]) | 40

Note: Searches conducted in June 2015

Table B-2 CINAHL literature search strings for nursing home patient safety categories

1 | “nursing home” OR “long-term care” OR “residential aged care” OR “skilled nursing facility” OR “aged care facility” OR “aged care facilities” | (33,522)
2 | “randomized” OR “cluster-randomized” OR “RCT” OR “trial” OR “systematic review” OR “systematic literature review” OR “cochrane” OR “meta-analysis” OR “comparative effectiveness” | (147,681)
3 | #1 AND #2 | (1,358)
4 | #2 Limited to - Published Date: 2005–2015; Exclude MEDLINE records | (216)
8 | (“nursing home” OR “long-term care” OR “residential aged care” OR “skilled nursing facility” OR “aged care facility” OR “aged care facilities”) AND (“Accidental Falls” OR “fall prevention” OR “preventing falls”) AND (“randomized” OR “cluster-randomized” OR “RCT” OR “trial” OR “systematic review” OR “systematic literature review” OR “cochrane” OR “meta-analysis” OR “comparative effectiveness”) Limiters - Published Date: 2005–2015; Exclude MEDLINE records | (10)
9 | (“nursing home” OR “long-term care” OR “residential aged care” OR “skilled nursing facility” OR “aged care facility” OR “aged care facilities”) AND “pain” AND (“randomized” OR “cluster-randomized” OR “RCT” OR “trial” OR “systematic review” OR “systematic literature review” OR “cochrane” OR “meta-analysis” OR “comparative effectiveness”) Limiters - Published Date: 2005–2015; Exclude MEDLINE records | (12)
10 | (“nursing home” OR “long-term care” OR “residential aged care” OR “skilled nursing facility” OR “aged care facility” OR “aged care facilities”) AND (“randomized” OR “cluster-randomized” OR “RCT” OR “trial” OR “systematic review” OR “systematic literature review” OR “cochrane” OR “meta-analysis” OR “comparative effectiveness”) AND (• “pressure ulcer” OR “decubitus ulcer” OR “bedsore” OR “pressure sore”) Limiters - Published Date: 2005–2015; Exclude MEDLINE records | (15)
11 | (“nursing home” OR “long-term care” OR “residential aged care” OR “skilled nursing facility” OR “aged care facility” OR “aged care facilities”) AND (“randomized” OR “cluster-randomized” OR “RCT” OR “trial” OR “systematic review” OR “systematic literature review” OR “cochrane” OR “meta-analysis” OR “comparative effectiveness”) AND (“Catheter-Related Infections” OR “urinary tract infections” OR “catheter-associated urinary tract infection” OR “CAUTI” or “UTI” or “urinary tract infection”) Limiters - Published Date: 2005–2015; Exclude MEDLINE records | (2)
12 | (“nursing home” OR “long-term care” OR “residential aged care” OR “skilled nursing facility” OR “aged care facility” OR “aged care facilities”) AND (“randomized” OR “cluster-randomized” OR “RCT” OR “trial” OR “systematic review” OR “systematic literature review” OR “cochrane” OR “meta-analysis” OR “comparative effectiveness”) AND (“Medication Error” OR “medication reconciliation” OR “reducing error”) Limiters - Published Date: 2005–2015; Exclude MEDLINE records | (0)
13 | (“nursing home” OR “long-term care” OR “residential aged care” OR “skilled nursing facility” OR “aged care facility” OR “aged care facilities”) AND (“randomized” OR “cluster-randomized” OR “RCT” OR “trial” OR “systematic review” OR “systematic literature review” OR “cochrane” OR “meta-analysis” OR “comparative effectiveness”) AND (“Infectious Disease Transmission” OR “healthcare associated infection” OR “HAI” OR “infection control”) Limiters - Published Date: 2005–2015; Exclude MEDLINE records | (4)
14 | (“nursing home” OR “long-term care” OR “residential aged care” OR “skilled nursing facility” OR “aged care facility” OR “aged care facilities”) AND (“randomized” OR “cluster-randomized” OR “RCT” OR “trial” OR “systematic review” OR “systematic literature review” OR “cochrane” OR “meta-analysis” OR “comparative effectiveness”) AND (“Quality Improvement” OR “Quality Indicator” OR “public reporting” OR “patient safety” OR “resident safety”) Limiters - Published Date: 2005–2015; Exclude MEDLINE records | (14)

## Cochrane Search String

((“nursing home” OR “aged care” OR “elderly care” OR “long-term care” OR “long term care” OR elderly OR “older people” OR “older adults”) AND (falls OR “pressure ulcer” OR “pressure ulcers” OR “infection” OR “HAI” OR “healthcare-associated infection” OR “urinary tract infection” OR “UTI” OR “medication error” OR “adverse drug event” OR “ADE” OR polypharmacy OR “weight loss” OR dehydration OR “activities of daily living” OR “ADL” OR “fecal incontinence” OR “urinary incontinence” OR incontinence OR “depressive symptoms” OR “antipsychotic medication” OR pain OR “influenza vaccine” OR “pneumococcal vaccine” OR “physical restraint” OR “physical restraints” OR (catheter AND bladder) )) AND limit to Cochrane Review =173

Conducted July 30,2015